# Screening for Congenital Hypothyroidism

## Burden of Suffering

In the U.S., congenital hypothyroidism occurs in 1 of 3,600-4,000 infants.^1,2^ Clinical diagnosis occurs in <5% of newborns with hypothyroidism because symptoms and signs are often minimal.^ 1 ^ Without prompt treatment, most affected children gradually develop growth failure, irreversible mental retardation, and a variety of neuropsychologic deficits, comprising the syndrome of cretinism.^1,2^ These complications have become rare since the introduction in the 1970s of routine neonatal screening and early treatment of congenital hypothyroidism.

## Accuracy of Screening Tests

In the U.S., screening for congenital hypothyroidism in neonates is almost always done by the radioimmunoassay of serum thyroxine (T_4_) and thyroid-stimulating hormone (TSH) from dried-blood spot specimens collected by heelstick and adsorbed onto filter paper.^3,4^ Laboratories in most of the U.S. measure T_4_ on all specimens, and TSH only if the T_4_ level is low in several states, most of Europe, and elsewhere in the world, TSH is the initial screening test.^3,5^ Simultaneous measurement of both T_4_ and TSH has greater sensitivity for congenital hypothyroidism than either of the two sequential methods currently used,^ 6 ^ but it is not considered cost-effective by most programs at this time.^5,7^ The T_4_ assay appears to have greater precision and reproducibility than the TSH assay, but false negative rates are similar with the two methods.^ 6 ^ Both types of screening may miss the 3-5% of cases of congenital hypothyroidism that are caused by pituitary dysfunction, as well as the 3-14% of cases in which patients present with hypothyroxinemia and delayed TSH elevation.^8-10^ The primary T_4_-supplemental TSH approach also misses some patients with residual thyroid tissue (i.e., ectopic gland) that results in initially normal T_4_ with elevated TSH sensitivity for these cases can be improved by repeat screening at 2-6 weeks.^ 11 ^ Using a higher cutoff point to define abnormal T_4_ results in fewer false negatives due to these biologic factors. In one population, using a cutoff of the lowest 5% of T_4_ values to define "low" missed 3.5% of cases, whereas using the lowest 10% resulted in 1.5% being missed.^ 12 ^ Only 0.2% of cases were missed using the lowest 20% as a cutoff, but at substantially increased cost in terms of repeat testing.

False negatives also occur due to screening errors. Such failures occur in specimen collection, laboratory procedures (e.g., failure to record an abnormal result), or follow-up.^ 13 ^ Standards for adequate blood collection on filter paper for neonatal screening programs have been published.^ 13a ^ Infants at increased risk for false negatives from screening errors include those born at home, ill at birth, or transferred between hospitals early in life.^ 2 ^ In North America, an estimated 6-12% of neonates with congenital hypothyroidism are not detected in screening programs as a result of biologic factors or screening errors.^8,13^

In established U.S. screening programs, there are 4-8 false positives for every proven case,^ 8 ^ although follow-up testing readily corrects these. Screening with primary TSH instead of T_4_-supplemental TSH may result in fewer false-positive tests.^8,14^ False-positive results are more likely when screening is done in the first 24-48 hours of life, since normal TSH values in the first 2 days of life may exceed the standard cutoff used by most programs.^ 15 ^ Evidence for long-term adverse psychologic effects from falsely positive screening test results is limited by methodologic flaws.^16-19^

## Effectiveness of Early Detection

Most cases of congenital hypothyroidism present clinically during the first year of life.^ 20 ^ Retrospective studies of patients with congenital hypothyroidism have reported that delay of diagnosis and treatment beyond the first 1-3 months of life is likely to result in irreversible neuropsychologic deficits.^21-25^ More recent prospective studies show that screening neonates and treating affected infants within the first weeks of life results, on average, in normal or near-normal intellectual performance and growth at ages 5-12 years.^26-34^ These children appear to have somewhat lower cognitive and motor development compared to sibling or classmate controls, however, and continue to manifest subtle deficits in language, perception, and motor skills.^27,28,31-35^ Both age at onset of therapy and quality of therapeutic control achieved during the first year of life affect long-term intellectual outcome, supportive evidence for a benefit from earlier detection and treatment.^27,28,31-33,35^ The reduced incidence of severe neuropsychologic effects observed with early, adequate treatment has prompted most Western governments to require routine screening for all neonates.

Screening at birth may, in fact, occur too late to prevent important neurodevelopmental deficits in some infants. Observational studies suggest that infants affected more severely in utero, as evidenced by greater delay in bone age at diagnosis, lower T_4_ at screening, or a diagnosis of thyroid agenesis, have significantly poorer developmental outcomes compared to those with milder disease or to normal controls, even when detected and treated in the newborn period.^28,31-36^

## Recommendations of Other Groups

Screening of newborns for hypothyroidism is offered in all states, but mandated in 46 states and the District of Columbia.^ 3 ^ Five states and the District of Columbia require or strongly recommend a routine second screening test, from 1 to 4 weeks later.^ 3 ^ Screening is recommended by the Canadian Task Force on the Periodic Health Examination,^ 37 ^ the American Academy of Family Physicians,^ 38 ^ Bright Futures,^ 39 ^ and jointly by the American Academy of Pediatrics and the American Thyroid Association.^ 5 ^

## Discussion

The natural history of congenital hypothyroidism has changed dramatically since newborn screening was instituted in this country.^ 2 ^ Before screening was available, many children with this disorder were at least moderately, and sometimes profoundly, retarded, while recent prospective studies have demonstrated normal or near-normal intelligence in virtually all of those detected by screening and treated early in life. There is thus good evidence to support screening for congenital hypothyroidism in the newborn.

CLINICAL INTERVENTION

Screening for congenital hypothyroidism with thyroid function tests performed on dried-blood spot specimens is recommended for all newborns, optimally between days 2 and 6, but in all cases before newborn nursery discharge ("A" recommendation). Blood specimens should be collected by heelstick, adsorbed onto filter paper, and air dried using standard technique.^ 13a ^ The choice of which thyroid function test or tests to perform is generally determined by individual state requirements.^ 3 ^ Testing procedures and follow-up treatment for abnormal results should follow current guidelines.^ 5 ^ Care should be taken to ensure that those born at home, ill at birth, or transferred between hospitals in the first week of life are appropriately screened before 7 days of age. Normal newborn screening results should not preclude appropriate evaluation of infants presenting with clinical symptoms and signs suggestive of hypothyroidism.

The draft update of this chapter was prepared for the U.S. Preventive Services Task Force by Carolyn DiGuiseppi, MD, MPH.

## REFERENCES, G.45. Congenital Hypothyroidism

1 Committee on Genetics, American Academy of Pediatrics. Newborn screening fact sheets. Pediatrics. 1989;83:449-464. [pmid: 2919149].
2 Willi SM, Moshang T Jr. Diagnostic dilemmas: results of screening tests for congenital hypothyroidism. Pediatr Clin North Am. 1991;38:555-566. [pmid: 2047138].
3 Newborn Screening Committee, The Council of Regional Networks for Genetic Services (CORN). National newborn screening report: 1991. New York: CORN, July. 1994.
4 Therrell BL Jr, ed. Laboratory methods for neonatal screening. Washington, DC: American Public Health Association. 1993.
5 American Academy of Pediatrics and American Thyroid Association. Newborn screening for congenital hypothyroidism: recommended guidelines. Pediatrics. 1993;91:1203-1209. [pmid: 8502532].
6 Dussault JH, Morissette J. Higher sensitivity of primary thyrotropin in screening for congenital hypothyroidism: a myth?. J Clin Endocrinol Metab. 1983;56:849-852. [pmid: 6833464].
7 Gruters A, Delange F, Giovanelli G, et al. Guidelines for neonatal screening programs for congenital hypothyroidism. European Society for Pediatric Endocrinology Working Group on Congenital Hypothyroidism. Horm Res. 1994;41:1-2. [pmid: 8013935].
8 Fisher DA. Effectiveness of newborn screening programs for congenital hypothyroidism: prevalence of missed cases. Pediatr Clin North Am. 1987;34:881-890. [pmid: 3302897].
9 Hanna CE, Krainz PL, Skeels MR, et al. Detection of congenital hypopituitary hypothyroidism: ten-year experience in the Northwest Regional Screening Program. J Pediatr. 1986;10:959-964.
10 de Zegher F, Vanderschueren-Lodeweyckx M, Heinrichs C, et al. Thyroid dyshormonogenesis: severe hypothyroidism after normal neonatal thyroid stimulating hormone screening. Acta Paediatr. 1992;81:274-276. [pmid: 1511207].
11 LaFranchi SH, Hanna CE, Krainz PL, et al. Screening for congenital hypothyroidism with specimen collection at two time periods: results of the Northwest Regional Screening Program. Pediatrics. 1985;76:734-740. [pmid: 3932955].
12 Verkerk PH, Buitendijk SE, Verloove-Vanhorick SP. Congenital hypothyroidism screening and the cutoff for thyrotropin measurement: recommendations from the Netherlands. Am J Public Health. 1993;83:868-871. [pmid: 8498626].
13 Holtzman C, Slazyk WE, Cordero JF, et al. Descriptive epidemiology of missed cases of phenylketonuria and congenital hypothyroidism. Pediatrics. 1986;78:553-558. [pmid: 3763262].
13A National Committee for Clinical Laboratory Standards. Blood collection on filter paper for neonatal screening programs, 2nd ed; approved standard. Vol 12 no 13. Villanova, PA. Villanova, PA. 1992;(NCCLS document LA4-A2.).
14 Pharoah POD, Madden MP. Audit of screening for congenital hypothyroidism. Arch Dis Child. 1992;67:1073-1076. [pmid: 1417047].
15 Allen DB, Sieger JE, Litsheim T, et al. Age-adjusted thyrotropin criteria for neonatal screening for hypothyroidism. J Pediatr. 1990;117:309-312. [pmid: 2199645].
16 Fyro K, Bodegard G. Four-year follow-up of psychological reactions to false positive screening tests for congenital hypothyroidism. Acta Paediatr Scand. 1987;76:107-114. [pmid: 3564986].
17 Fyro K, Bodegard G. Difficulties in psychological adjustment to a new neonatal screening programme. Acta Paediatr Scand. 1988;77:226-231. [pmid: 3354333].
18 Bodegard G, Fyro K, Larsson A. Psychological reactions in 102 families with a newborn who has a falsely positive screening test for congenital hypothyroidism. Acta Paediatr Scand. 1983;304 (suppl):1-21.
19 Fisher DA, Dussault JH, Foley TP, et al. Screening for congenital hypothyroidism: results of screening one million North American infants. J Pediatr. 1979;94:700-705. [pmid: 87512].
20 Alm J, Larsson A, Zetterstrom R. Congenital hypothyroidism in Sweden: incidence and age at diagnosis. Acta Paediatr Scand. 1978;67:1-3. [pmid: 626059].
21 Raiti S, Newns GH. Cretinism: early diagnosis and its relation to mental prognosis. Arch Dis Child. 1971;46:692-694. [pmid: 5118058].
22 Alm J, Larsson A, Zetterstrom R. Congenital hypothyroidism in Sweden. Psychomotor development in patients detected by clinical signs and symptoms. Acta Paediatr Scand. 1981;70:907-912. [pmid: 7324945].
23 Hulse JA. Outcome for congenital hypothyroidism. Arch Dis Child. 1984;59:23-29. [pmid: 6198974].
24 Klein AH, Meltzer S, Kenny FM. Improved prognosis in congenital hypothyroidism treated before age three months. J Pediatr. 1972;81:912-915. [pmid: 5086719].
25 Alm J, Hagenfeldt L, Larsson A, et al. Incidence of congenital hypothyroidism: retrospective study of neonatal laboratory screening versus clinical symptoms as indicators leading to diagnosis. BMJ. 1984;289:1171-1175. [pmid: 6437473].
26 New England Congenital Hypothyroidism Collaborative. Elementary school performance of children with congenital hypothyroidism. J Pediatr. 1990;116:27-32. [pmid: 2295961].
27 Heyerdahl S, Kase BF, Lie SO. Intellectual development in children with congenital hypothyroidism in relation to recommended thyroxine treatment. J Pediatr. 1991;118:850-857. [pmid: 2040919].
28 Toublanc JE, Rives S, Acosta A, et al. Le développement psychomoteur et intellectuel chez 52 enfants atteints d'hypothyroidie congénitale dépistée à la naissance: eléments susceptibles d'influer sur le pronostic. Arch Fr Pediatr. 1990;47:191-195. [pmid: 1693066].
29 Ilicki A, Larsson A. Psychological development at 7 years of age in children with congenital hypothyroidism: timing and dosage of initial treatment. Acta Paediatr Scand. 1991;80:199-200. [pmid: 2035311].
30 Aronson R, Ehrlich RM, Bailey JD, Rovet JF. Growth in children with congenital hypothyroidism detected by neonatal screening. J Pediatr. 1990;116:33-37. [pmid: 2295962].
31 Glorieux J, Dussault J, Van Vliet G. Intellectual development at age 12 years of children with congenital hypothyroidism diagnosed by neonatal screening. J Pediatr. 1992;121:581-584. [pmid: 1403394].
32 Rovet JF, Ehrlich RM, Sorbara DL. Neurodevelopment in infants and preschool children with congenital hypothyroidism: etiological and treatment factors affecting outcome. J Pediatr Psychol. 1992;17:187-213. [pmid: 1593394].
33 Kooistra L, Laane C, Vulsma T, et al. Motor and cognitive development in children with congenital hypothyroidism: a long-term evaluation of the effects of neonatal treatment. J Pediatr. 1994;124:903-909. [pmid: 8201474].
34 Fuggle PW, Grant DB, Smith I, et al. Intelligence, motor skills and behaviour at 5 years in early-treated congenital hypothyroidism. Eur J Pediatr. 1991;150:570-574. [pmid: 1954963].
35 Virtanen M, Santavuori P, Hirvonen E, et al. Multivariate analysis of psychomotor development in congenital hypothyroidism. Acta Paediatr Scand. 1989;78:405-411. [pmid: 2741682].
36 Chiovato L, Giusti L, Tonacchera M, et al. Evaluation of l-thyroxine replacement therapy in children with congenital hypothyroidism. J Endocrinol Invest. 1991;14:957-964. [pmid: 1806614].
37 Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical preventive health care. Ottawa: Canada Communication Group. 1994:190-194.
38 American Academy of Family Physicians. Age charts for periodic health examination. Kansas City, MO: American Academy of Family Physicians. 1994. (Reprint no. 510.).
39 Green M, ed. Bright Futures: guidelines for health supervision of infants, children and adolescents. Arlington VA: National Center for Education in Maternal and Child Health. 1994.