# Screening for Genital Herpes Simplex

## Burden of Suffering

Primary genital herpes simplex virus (HSV) infection occurs in approximately 200,000-500,000 Americans each year,^ 1 ^ mostly in adolescents and young adults. Between 25 and 31 million individuals are chronically infected.^1,2^ Both HSV types 1 (HSV-1) and 2 (HSV-2) can infect the genitalia, but HSV-2 causes the majority of primary and recurrent genital herpes infections.^ 3 ^ Most HSV-2 infections are asymptomatic, detected only by seroconversion^4,5^ 16% of the adult population is HSV-2 seropositive.^ 2 ^ In symptomatic genital herpes, the chief clinical morbidity is painful, pruritic vesicles that may coalesce into large ulcerative lesions.^ 3 ^ Systemic symptoms, such as fever, headache, myalgia, and malaise, are reported by two thirds of patients with primary first-episode genital herpes, and serious complications such as meningitis (reported in 8%) may ensue.^ 3 ^ After initial infection, the virus enters a latent state in spinal cord ganglia. Infected persons may periodically experience viral reactivations that can be asymptomatic, characterized by viral shedding alone, or symptomatic, marked by a recurrence of signs and symptoms that are less severe than those of primary genital herpes.^ 3 ^ The sexual contacts of individuals with either symptomatic or asymptomatic disease are at risk of becoming infected.^ 6 ^

In pregnant women, the rate of genital herpes reported as a maternal risk factor on birth certificates is 8.0/1,000 live births.^ 7 ^ Pregnant women with genital HSV infection can transmit the virus to their newborns. The majority (82-87%) of neonatal infections occur during delivery, but some also occur in utero or postnatally.^8-10^ In 1984 it was estimated that the minimum annual incidence of neonatal HSV infections in the United States, based on voluntary reporting, was 4/100,000 live births^ 11 ^ intensive local surveillance in one county in Washington found a rate of 12/100,000 live births.^ 12 ^ One fourth of HSV-infected neonates develop disseminated disease and one third have encephalitis.^13,14^ Even with antiviral treatment, the mortality rate is 57% among infants with disseminated disease and 15% among those with encephalitis.^ 13 ^ Severe neurologic impairment occurs in about one third of those who survive encephalitis or disseminated disease.^13,14^ Among infants with infection apparently limited to mucocutaneous involvement, death or severe impairment is rare but other complications such as visual impairment or seizures occur in about 5%.^13,14^

## Accuracy of Screening Tests

History and physical examination are not adequate screening tests for either active (i.e., transmissible) or latent genital HSV infection, because most infected persons are asymptomatic^4,5,15^ their clinical manifestations may resemble a number of other causes of genital ulcerations^ 16 ^ and viral shedding in association with recurrent disease may be asymptomatic.^3,17^

The most commonly used test for detecting active genital HSV infection is viral culture. The sensitivity of this test is variable, however, depending upon the viral titer present, ranging in one study from 93% for vesicles to 72% for ulcers and 27% for crusted lesions, and from 82% for ulcerative lesions in first episodes to 43% for ulcerative lesions in recurrent episodes.^16,18^ Since the viral titer in asymptomatic shedding is 10-100 times less than that in symptomatic episodes,^ 17 ^ the sensitivity of viral culture for detecting HSV infection in asymptomatic individuals is likely to be low. In addition, conventional viral culture is time-consuming and technically demanding, and only 40-48% of positive results are available within 24 hours.^19-21^ Viral culture techniques may be modified to produce final test results within 16-24 hours, but sensitivity is then reduced by 5-20% compared with final conventional culture results in symptomatic patients^20-24^ sensitivity is likely to be reduced further in asymptomatic patients.

Other rapid screening methods, such as cytology and direct fluorescent antibody staining, are widely available but are substantially less sensitive than is conventional viral culture.^ 6 ^ Newer methods, not yet licensed for clinical diagnostic testing for HSV, include enzyme immunoassay (EIA), polymerase chain reaction (PCR), and DNA hybridization. EIA and PCR show concordance of >93% with the results of conventional viral culture in symptomatic women.^25-28^ In one study in asymptomatic pregnant women, PCR had a reported concordance of 100% with conventional culture.^ 27 ^ EIA, however, had a concordance of only 59% with conventional viral culture in a large study of samples taken primarily from "presumed asymptomatic" pregnant women.^ 25 ^ EIA can provide results within several hours, whereas even with automated techniques PCR currently requires more than a day to process and is extremely labor intensive. Both EIA and PCR may react with nonviable virus or viral particles,^25-28^ thus overestimating the risk of infectivity. Results from studies of DNA hybridization appear less promising, with a sensitivity of 25% and specificity of 88% compared to conventional culture,^ 22 ^ and 43% and 71%, respectively, compared to cytology,^ 29 ^ on samples from symptomatic patients.

An estimated 35-80% of infants with neonatal herpes are born to women with no known history of genital herpes or physical signs of infection at delivery.^10,12,13^ Therefore, screening asymptomatic pregnant women has the potential of identifying unrecognized active HSV infections. In order for routine screening at the onset of labor to be useful for clinical decision making regarding surgical or medical intervention to prevent neonatal herpes, rapid and accurate methods of detecting asymptomatic HSV infections likely to be transmitted would be needed. The yield of routine screening by viral culture in asymptomatic pregnant women is quite low large-scale screening studies have isolated HSV by culture from only 0.20-0.35% at the time of delivery.^30-32^ A positive viral culture does not necessarily mean an infant will become infected during delivery. The risk of acquiring neonatal herpes infection from an asymptomatic pregnant woman with active viral shedding from reactivated disease is less than 5%, whereas from a woman with first-episode genital disease the risk is 33%.^ 31 ^ A negative culture, however, does not eliminate an infant's risk of infection. In one large cohort study, the mothers of 30% (3 of 10) of the infected newborns were culture negative at the time of delivery,^ 31 ^ and in a case series of infants with neonatal herpes, 61% (54 of 89) of the pregnant women had negative cultures within the 2 weeks before delivery.^ 33 ^ In asymptomatic women with a history of recurrent herpes, surveillance cultures during the 4 weeks before delivery did not correlate with viral shedding at delivery.^ 34 ^ Thus, screening near term is not adequate to predict accurately the likelihood of HSV transmission from asymptomatic pregnant women to their offspring.

Antibody testing can accurately distinguish HSV-seropositive from HSV-seronegative persons and therefore may be useful to detect asymptomatic carriers at potential risk for transmitting disease, as well as persons susceptible to primary infection. Commercial assays are insensitive to recent infections, however, and they are unreliable for distinguishing HSV-2 from HSV-1 antibodies.^35,36^ Antibody test results do not indicate whether the virus is currently capable of being transmitted.

## Effectiveness of Early Detection

The detection of HSV infection in asymptomatic, nonpregnant individuals would be useful if treatment were available to either eradicate latent HSV infection or to prevent transmission to sex partners by eliminating or reducing viral shedding. There is currently no effective treatment for eradicating latent herpes infection. Both episodic and continuous oral acyclovir reduce viral shedding, lesion healing time, and local and systemic symptoms during symptomatic primary first-episode and recurrent genital HSV infections.^37-42^ When used continuously for up to 4 years, oral acyclovir produces only minor side effects and minimal emergence of resistant strains in immunologically normal individuals.^41-43^ The beneficial effects of acyclovir on lesion healing and viral shedding in symptomatic individuals have not been documented to prevent or reduce transmission to sex partners, however. Based on a single, small before-after study, oral acyclovir does not appear to prevent asymptomatic viral shedding,^ 44 ^ and no studies have evaluated its ability to decrease infectivity and disease transmission during episodes of asymptomatic shedding.

Routine screening for HSV-2 antibodies may be useful to identify persons with previously unrecognized infection,^ 4 ^ who could then be instructed in the recognition of recurrent episodes. Such instruction results in recognition of clinically symptomatic genital herpes on follow-up in 50% of seropositive persons with previously unrecognized infection.^ 45 ^ Counseling seropositive persons to avoid sexual activity or to use condoms during symptomatic episodes may reduce transmission of herpes to their sex partners.^45,46^ Among a series of 144 couples with one partner with recurrent herpes and one without antibody, all of whom were advised to abstain from skin-to-skin contact during active episodes and about the risks of transmission during asymptomatic periods, acquisition of genital herpes occurred in 6% who used barrier contraception and 14% who did not (p = 0.19), but only 15% of couples used condoms routinely.^ 47 ^ Although not specifically designed to evaluate counseling, this study suggests a limited benefit from knowledge of susceptibility. The effectiveness of this strategy in preventing HSV-2 transmission has not been evaluated adequately it may not provide any incremental benefit over routine counseling of all sexually active adults regarding prevention of sexually transmitted diseases.^ 48 ^

The early detection of active HSV infection may be of greater importance during pregnancy because cesarean delivery can be performed. This has the potential to reduce the exposure of the neonate to virus in the birth canal that occurs during vaginal delivery, although the evidence for the effectiveness of this intervention is limited. Small, uncontrolled case series of symptomatic women with positive genital cultures during the 1-2 weeks before delivery^49,50^ or with positive cervical cultures at the time of delivery^ 51 ^ suggest a protective effect of cesarean deliveries no controlled trials have evaluated this intervention. None of these studies differentiated primary from recurrent infections, which have different rates of HSV transmission. Cesarean delivery is clearly not completely effective, since large case series of newborns infected with HSV reveal that 19-33% of them were delivered by cesarean delivery.^11,33,52^ Information concerning the effectiveness of cesarean delivery in preventing neonatal herpes transmission by asymptomatic pregnant women comes from a large cohort study that screened such women by viral culture during early labor.^ 31 ^ In this study, 8% (1 of 13) of infants delivered by cesarean delivery to culture-positive women became infected, compared to 14% (6 of 43) of infants delivered vaginally to culture-positive women. Drawing conclusions from this study is difficult, however, because sample size was insufficient to establish statistical significance reasons for selection of vaginal delivery are not given and differences between the two groups in the proportions of primary versus recurrent infections, site of positive culture (i.e., cervical vs. other), and duration of rupture of membranes are not delineated. Thus, the benefit of cesarean delivery in either symptomatic or asymptomatic culture-positive women is not established.

Even if cesarean delivery does offer some benefit in preventing the transmission of HSV to newborns, more definitive studies would be needed to determine the proper indications for abdominal delivery. For example, it is not clear whether cesarean delivery would be indicated when the risk of herpes transmission is low, e.g., in the setting of asymptomatic viral shedding, recurrent symptomatic disease, or when labial but not cervical cultures are positive.^31,34,51,53^ In these relatively low-risk situations, the potential benefit to the fetus of averting HSV infection may not outweigh the known risk of complications in the mother and infant due to cesarean delivery. In cohort studies, cesarean delivery has been associated with increases in both maternal morbidity and mortality compared to vaginal delivery,^54-56^ even when stratified by maternal diagnosis. A 1993 decision analysis model calculated that cesarean delivery for herpes lesions at delivery in women with recurrent genital HSV leads to 1,580 excess (i.e., performed solely to prevent HSV transmission) cesarean deliveries for every neonate saved from death or neurologic sequelae, and 0.57 maternal deaths for every neonatal death prevented total costs were $2.5 million per case of HSV averted, and $203,000 per quality adjusted life-year (QALY) gained.^ 57 ^ These estimates are sensitive to risk of vertical transmission (estimated to be 1%) and to the efficacy of cesarean delivery (estimated to be 80%) reductions in either of these could result in maternal deaths exceeding neonatal mortality. The decision analysis results change dramatically if only women with primary HSV infections are entered. In women with herpes lesions at delivery but no previous history of genital HSV, nine excess cesarean deliveries would be performed for every neonate saved, with 0.004 maternal deaths per neonatal death prevented, at a total savings of more than $38,000, saving $2600 per QALY gained. Net benefits persisted across all likely ranges of values entered into the model.

Serologic screening may prove useful for the prevention of primary HSV-2 infections in pregnancy. One study screened pregnant women and their partners for type-specific antibodies to herpes, and found that 10% (18 of 190) of the women were seronegative with seropositive partners, and therefore were at risk of contracting a primary HSV-2 infection during pregnancy 7 of 18 couples continued to have unprotected intercourse after being informed of their serologic status, and 1 of the 7 seroconverted during pregnancy.^ 5 ^ Studies evaluating the effectiveness of counseling such couples to abstain from sexual intercourse or to use condoms regularly during pregnancy to prevent neonatal herpes transmission have not been performed.

Another potential strategy for preventing the transmission of HSV to newborns is offering prophylactic acyclovir to pregnant women with recurrent herpes. A case series of 15 pregnant women with recurrent genital herpes demonstrated that suppressive treatment with acyclovir after 38 weeks of gestation was well tolerated with no toxicity to the mothers or infants.^ 58 ^ None of the women experienced new symptomatic recurrences or asymptomatic viral shedding after beginning treatment and none of their infants developed neonatal infection. In a pilot randomized controlled trial, women with recurrent herpes who received acyclovir continuously at least 1 week before expected term had significantly fewer HSV recurrences/positive cultures and a significantly lower rate of cesarean delivery for herpes.^ 59 ^ Four randomized controlled studies are currently being conducted, in the United States, Norway, and England, to determine the effectiveness and safety of prophylactic acyclovir in reducing the risks of asymptomatic shedding, cesarean delivery, and neonatal transmission when given in late pregnancy to women with histories of recurrent herpes (H. Watts, personal communication, July 1995 L. Scott, personal communication, July 1995).^60,61^ Although acyclovir has not been found to be teratogenic in standard animal testing, and no recognizable pattern of birth defects has been detected among 601 reported cases of exposure during pregnancy, current data are only sufficient to exclude a teratogenic risk of at least 2-fold over the 3% baseline risk of birth defects.^62,63^

## Recommendations of Other Groups

The American College of Obstetricians and Gynecologists,^ 64 ^ the American Academy of Pediatrics,^ 65 ^ the Canadian Task Force on the Periodic Health Examination,^ 66 ^ and the Infectious Disease Society of America^ 67 ^ recommend against surveillance cultures for herpes infections in asymptomatic pregnant women. All four groups suggest careful examination of all women at the time of delivery and culture of active lesions, with cesarean delivery for women with positive findings on clinical examination.^64-67^ No organizations currently recommend screening for genital herpes simplex virus or antibody in the asymptomatic general population.

## Discussion

There are currently no commercially available tests that are adequate to detect latent HSV-2 infections in asymptomatic patients. Even if accurate type-specific serology becomes widely available, there is no proven treatment to eradicate latent infection or to eliminate viral shedding in order to prevent disease transmission. Similarly, there is limited evidence that counseling persons known to have HSV offers any benefit over routine counseling of all sexually active adults to prevent sexually transmitted diseases. Evidence does not therefore support screening the asymptomatic general population for HSV infection.

For pregnant women (and those planning conception), the potential benefit of detecting asymptomatic and unrecognized HSV infection is the prevention of neonatal HSV transmission. The risk of transmitting HSV to their infants is slightly increased in pregnant women with asymptomatic shedding of HSV due to reactivated disease at delivery, and it is substantially increased in women with primary HSV infection at delivery. Culture results at the onset of labor are rarely available in time to affect clinical decision making, and there is good evidence that positive viral cultures in the weeks prior to delivery do not accurately predict the risk of neonatal HSV transmission. More rapid tests that could be performed at the onset of labor are either substantially less sensitive than culture or not yet widely available. Women with primary first-episode HSV infection at delivery are more likely to present with symptoms and signs detectable by physical examination, but such examinations have not been shown to be sensitive or specific. Even if the diagnosis of HSV is made by physical examination during labor, the evidence supporting the effectiveness of cesarean delivery in preventing neonatal HSV transmission is of poor quality, while there is fair evidence that cesarean delivery increases risk to the mother and fetus compared to vaginal delivery. A recent decision analysis predicts that if cesarean delivery prevents 85% of neonatal HSV infections that occur following vaginal delivery, a physical examination at labor for symptoms or signs of genital herpes would minimize the ratio of excess cesarean deliveries to cases of neonatal HSV infection averted, compared to other screening methods or no screening.^ 68 ^ Another model that evaluated performing a physical examination at delivery, followed by cesarean delivery for women with genital herpes lesions, found clear evidence of benefit only for women with no history of genital herpes.^ 57 ^ For women with recurrent herpes, the risk to the mother may outweigh that to the neonate, depending on assumptions made about the efficacy of cesarean delivery and the likely HSV transmission rate. The use of acyclovir in pregnancy to reduce neonatal HSV has not been adequately evaluated, but trials are ongoing.

Although a history of genital herpes does not accurately predict HSV seropositivity, if the pregnant woman who lacks such a history has a partner known to have genital herpes, counseling to prevent HSV transmission to the woman could prevent primary HSV infection, thereby preventing neonatal HSV at little cost or risk to the patient. When commercially available, HSV serotyping at the first prenatal visit with serotesting of the partners of those who are HSV-2 seronegative would allow more accurate detection of pregnant women at risk for primary HSV infection. The effectiveness of counseling such women regarding primary prevention has not been demonstrated, however.

CLINICAL INTERVENTION

Routine screening for genital herpes simplex in asymptomatic persons, using culture, serology, or other tests, is not recommended ("D" recommendation). See Chapter 62 for recommendations on counseling to prevent sexually transmitted diseases.

Routine screening for genital herpes simplex infection in asymptomatic pregnant women, by surveillance cultures or serology, is also not recommended ("D" recommendation). Clinicians should take a complete sexual history on all adolescent and adult patients (see Chapter 62).

As part of the sexual history, clinicians should consider asking all pregnant women at the first prenatal visit whether they or their sex partner(s) have had genital herpetic lesions. There is insufficient evidence to recommend for or against routine counseling of women who have no history of genital herpes, but whose partners do have a positive history, to use condoms or abstain from intercourse during pregnancy ("C" recommendation) such counseling may be recommended, however, on other grounds, such as the lack of health risk and potential benefits of such behavior.

There is also insufficient evidence to recommend for or against the examination of all pregnant women for signs of active genital HSV lesions during labor and the performance of cesarean delivery on those with lesions ("C" recommendation) recommendations to do so may be made on other grounds, such as the results of decision analyses and expert opinion. There is not yet sufficient evidence to recommend for or against routine use of systemic acyclovir in pregnant women with recurrent herpes to prevent reactivations near term ("C" recommendation).

The draft update of this chapter was prepared for the U.S. Preventive Services Task Force by Paul Denning, MD, MPH, and Carolyn DiGuiseppi, MD, MPH.

## REFERENCES, D.30. Genital Herpes Simplex

1 Centers for Disease Control and Prevention, Division of STD/HIV Prevention. 1993 annual report. Atlanta: Centers for Disease Control and Prevention. 1994.
2 Johnson RE, Nahmias AJ, Magder LS, et al. A seroepidemiologic survey of the prevalence of herpes simplex virus type 2 infection in the United States. N Engl J Med. 1989;321:7-12. [pmid: 2543928].
3 Corey L, Adams HG, Brown ZA, et al. Genital herpes simplex virus infections: clinical manifestations, course, and complications. Ann Intern Med. 1983;98:973-983. [pmid: 6344713].
4 Koutsky LA, Stevens CE, Holmes KK, et al. Underdiagnosis of genital herpes by current clinical and viral-isolation procedures. N Engl J Med. 1992;326:1533-1539. [pmid: 1315930].
5 Kulhanjian JA, Soroush V, Au DS, et al. Identification of women at unsuspected risk of primary infection with herpes simplex virus type 2 during pregnancy. N Engl J Med. 1992;326:916-920. [pmid: 1311799].
6 Mertz GJ. Genital herpes simplex virus infections. Med Clin North Am. 1990;74:1433-1454. [pmid: 2246948].
7 Ventura SJ, Martin JA, Taffel SM, et al. Advance report of final natality statistics. Monthly vital statistics report; vol 43 no 5 (suppl). Hyattsville, MD: National Center for Health Statistics. 1994.
8 Baldwin S, Whitley RJ. Teratogen update: intrauterine herpes simplex virus infection. Teratology. 1989;39:1-10. [pmid: 2655150].
9 Hutto C, Arvin A, Jacobs R, et al. Intrauterine herpes simplex virus infections. J Pediatr. 1987;110:97-101. [pmid: 3794894].
10 Yeager AS, Arvin AM. Reasons for the absence of a history of recurrent genital infections in mothers of neonates infected with herpes simplex virus. Pediatrics. 1984;73:188-193. [pmid: 6538039].
11 Stone KM, Brooks CA, Guinan ME, et al. National surveillance for neonatal herpes simplex virus infections. Sex Transm Dis. 1989;16:152-156. [pmid: 2554515].
12 Sullivan-Bolyai J, Jull Hull HF, Wilson C, et al. Neonatal herpes simplex virus infection in King County, Washington: increasing incidence and epidemiologic correlates. JAMA. 1983;250:3059-3062. [pmid: 6315977].
13 Whitley R, Arvin A, Prober C, et al. Predictors of morbidity and mortality in neonates with herpes simplex virus infections. The National Institute of Allergy and Infectious Diseases Collaborative Antiviral Study Group. N Engl J Med. 1991;324:450-454. [pmid: 1988830].
14 Whitley R, Arvin A, Prober C, et al. A controlled trial comparing vidarabine with acyclovir in neonatal herpes simplex virus infection. N Engl J Med. 1991;324:444-449. [pmid: 1988829].
15 Koelle DM, Benedetti J, Langenberg A, et al. Asymptomatic reactivation of herpes simplex virus in women after the first episode of genital herpes. Ann Intern Med. 1992;116:433-437. [pmid: 1310837].
16 Corey L, Holmes KK. Genital herpes simplex virus infections: current concepts in diagnosis, therapy, and prevention. Ann Intern Med. 1983;98:973-983. [pmid: 6344713].
17 Corey L, Spear PG. Infections with herpes simplex viruses (pt 1 of 2). N Engl J Med. 1986;314:686-691. [pmid: 3005858].
18 Mosely Moseley RC, Corey L, Benjamin D, et al. Comparison of viral isolation, direct immunofluorescence, and indirect immunoperoxidase techniques for detection of genital herpes simplex virus infection. J Clin Microbiol. 1981;13:913-918. [pmid: 6263945].
19 Zimmerman SJ, Moses E, Sofat N, et al. Evaluation of a visual, rapid, membrane enzyme immunoassay for the detection of herpes simplex virus antigen. J Clin Microbiol. 1991;29:842-845. [pmid: 1653788].
20 Espy MJ, Wold AD, Jespersen DJ, et al. Comparison of shell vials and conventional tubes seeded with rhabdomyosarcoma and MRC-5 cells for the rapid detection of herpes simplex virus. J Clin Microbiol. 1991;29:2701-2703. [pmid: 1661744].
21 Johnston SL, Siegel CS. Comparison of enzyme immunoassay, shell vial culture, and conventional cell culture for the rapid detection of herpes simplex virus. Diagn Microbiol Infect Dis. 1990;13:241-244. [pmid: 2166633].
22 Seal LA, Toyama PS, Fleet KM, et al. Comparison of standard culture methods, a shell vial assay, and a DNA probe for the detection of herpes simplex virus. J Clin Microbiol. 1991;29:650-652. [pmid: 1645373].
23 Johnson FB, Luker G, Chow C. Comparison of shell vial culture and the suspension-infection method for the rapid detection of herpes simplex viruses. Diagn Microbiol Infect Dis. 1993;16:61-66. [pmid: 8381064].
24 Johnson FB, Visick EM. A rapid culture alternative to the shell-vial method for the detection of herpes simplex virus. Diagn Microbiol Infect Dis. 1992;15:673-678. [pmid: 1335863].
25 Verano L, Michalski FJ. Herpes simplex virus antigen direct detection in standard virus transport medium by DuPont Herpchek enzyme-linked immunosorbent assay. J Clin Microbiol. 1990;28:2555-2558. [pmid: 2174903].
26 Baker DA, Pavan-Langston D, Gonik B, et al. Multicenter clinical evaluation of the DuPont Herpchek HSV ELISA, a new rapid diagnostic test for the direct detection of herpes simplex virus. Adv Exp Med Biol. 1990;263:71-76. [pmid: 2162132].
27 Hardy DA, Arvin AM, Yasukawa LL, et al. Use of polymerase chain reaction for successful identification of asymptomatic genital infection with herpes simplex virus in pregnant women at delivery. J Infect Dis. 1990;162:1031-1035. [pmid: 2172392].
28 Gonik B, Seibel M, Berkowitz A, et al. Comparison of two enzyme-linked immunosorbent assays for detection of herpes simplex virus antigen. J Clin Microbiol. 1991;29:436-438. [pmid: 1645366].
29 Kobayashi TK. Comparison of immunocytochemistry and in situ hybridization in the cytodiagnosis of genital herpetic infection. Diagn Cytopathol. 1992;8:53-60. [pmid: 1312926].
30 Simkovich JW, Soper DE. Asymptomatic shedding of herpesvirus during labor. Am J Obstet Gynecol. 1988;158:588-589. [pmid: 2831720].
31 Brown ZA, Benedetti J, Ashley R, et al. Neonatal herpes simplex virus infection in relation to asymptomatic maternal infection at the time of labor. N Engl J Med. 1991;324:1247-1252. [pmid: 1849612].
32 Prober CG, Hensleigh PA, Boucher FD, et al. Use of routine viral cultures at delivery to identify neonates exposed to herpes simplex virus. N Engl J Med. 1988;318:887-891. [pmid: 2832756].
33 Whitley RJ, Corey L, Arvin A, et al. Changing presentation of herpes simplex virus infection in neonates. J Infect Dis. 1988;158:109-116. [pmid: 3392410].
34 Arvin AM, Hensleigh PA, Prober CG, et al. Failure of antepartum maternal cultures to predict the infant's risk of exposure to herpes simplex virus at delivery. N Engl J Med. 1986;315:796-800. [pmid: 3018565].
35 Nahmias AJ, Lee FK, Pereira L, et al Monoclonal antibody immunoaffinity purified glycoprotein for the detection of herpes simplex virus type 1 and type 2 specific antibodies in serumIn: Lopez C, Roizman B, eds. Human herpesvirus infections: pathogenesis, diagnosis, and treatment. , New York:Raven Press,1986 203 210 324626
36 Ashley R, Cent A, Maggs V, et al. Inability of enzyme immunoassays to discriminate between infections with herpes simplex virus types 1 and 2. Ann Intern Med. 1991;115:520-526. [pmid: 1652909].
37 Bryson YJ, Dillon M, Lovett M, et al. Treatment of first episodes of genital herpes simplex virus infection with oral acyclovir. N Engl J Med. 1983;308:916-921. [pmid: 6339923].
38 Nilsen AE, Aasen T, Halsos AM, et al. Efficacy of oral acyclovir in the treatment of initial and recurrent genital herpes. Lancet. 1982;2:571-573. [pmid: 6125728].
39 Mertz GJ, Critchlow CW, Benedetti J, et al. Double-blind placebo-controlled trial of oral acyclovir in first-episode genital herpes simplex virus infection. JAMA. 1984;252:1147-1151. [pmid: 6088819].
40 Reichman RC, Badger GJ, Mertz GJ, et al. Treatment of recurrent genital herpes simplex infections with oral acyclovir: a controlled trial. JAMA. 1984;251:2103-2107. [pmid: 6368877].
41 Baker DA, Blythe JG, Kaufman R, et al. One-year suppression of frequent recurrences of genital herpes with oral acyclovir. Obstet Gynecol. 1989;73:84-87. [pmid: 2642329].
42 Kaplowitz LG, Baker D, Gelb L, et al. Prolonged continuous acyclovir treatment of normal adults with frequently recurring genital herpes simplex virus infection. JAMA. 1991;265:747-751. [pmid: 1990191].
43 Molin L, Ruhnek-Forsbeck M, Svennerholm B. One year acyclovir suppression of frequently recurring genital herpes: a study of efficacy, safety, virus sensitivity and antibody response. Scand J Infect Dis Suppl. 1991;80:33-39. [pmid: 1666444].
44 Straus SE, Seidlin M, Takiff HE, et al. Effect of oral acyclovir treatment on symptomatic and asymptomatic virus shedding in recurrent genital herpes. Sex Transm Dis. 1989;16:107-113. [pmid: 2545002].
45 Langenberg A, Benedetti J, Jenkins J, et al. Development of clinically recognizable genital lesions among women previously identified as having "asymptomatic" herpes simplex virus type 2 infection. Ann Intern Med. 1989;110:882-887. [pmid: 2541645].
46 Corey L, Koutsky LA. Underdiagnosis of genital herpes [letter]. N Engl J Med. 1992;327.
47 Mertz GJ, Benedetti J, Ashley R, et al. Risk factors for the sexual transmission of genital herpes. Ann Intern Med. 1992;116:197-202. [pmid: 1309413].
48 Kaplan J. Underdiagnosis of genital herpes [letter]. N Engl J Med. 1992;327:1098-1099. [pmid: 1326079].
49 Grossman JH, Wallen WC, Sever JL. Management of genital herpes simplex virus infection during pregnancy. Obstet Gynecol. 1981;58:1-4. [pmid: 7195529].
50 Boehm FH, Estes W, Wright PF, et al. Management of genital herpes simplex virus infection occurring during pregnancy. Am J Obstet Gynecol. 1981;141:735-740. [pmid: 6274194].
51 Nahmias AJ, Josey WE, Naib ZM, et al. Perinatal risk associated with maternal genital herpes simplex virus infection. Am J Obstet Gynecol. 1971;110:825-834. [pmid: 4327295].
52 Koskiniemi M, Happonen J-M JM, Jarvenpaa A-L AL, et al. Neonatal herpes simplex virus infection: a report of 43 patients. Pediatr Infect Dis J. 1989;8:30-35. [pmid: 2537945].
53 Prober CG, Sullender WM, Yasukawa LL, et al. Low risk of herpes simplex virus infections in neonates exposed to the virus at the time of vaginal delivery to mothers with recurrent genital herpes simplex virus infections. N Engl J Med. 1987;316:240-244. [pmid: 3025727].
54 Bashore RA, Phillips WH Jr, Brinkman CR 3d. A comparison of the morbidity of midforceps and cesarean delivery. Am J Obstet Gynecol. 1990;162:1428-1434. [pmid: 2360575].
55 Petitti DB, Cefalo RC, Shapiro S, et al. In-hospital maternal mortality in the United States: time trends and relation to method of delivery. Obstet Gynecol. 1982;59:6-12. [pmid: 7078850].
56 Lehmann DK, Mabie WC, Miller JM Jr, et al. The epidemiology and pathology of maternal mortality: Charity Hospital of Louisiana in New Orleans, 1965-1984. Obstet Gynecol. 1987;69:833-840. [pmid: 3574812].
57 Randolph AG, Washington AE, Prober CG. Cesarean delivery for women presenting with genital herpes lesions. Efficacy, risks, and costs. JAMA. 1993;270:77-82. [pmid: 8510301].
58 Frenkel LM, Brown ZA, Bryson YJ, et al. Pharmacokinetics of acyclovir in the term human pregnancy and neonate. Am J Obstet Gynecol. 1991;164:569-576. [pmid: 1847004].
59 Stray-Pedersen B. Acyclovir in late pregnancy to prevent neonatal herpes simplex [letter]. Lancet. 1990;336.
60 Brocklehurst P, Carney O, Helson K, et al. Acyclovir, herpes, and pregnancy [letter]. Lancet. 1990;336:1594-1595. [pmid: 1979417].
61 Stray-Pedersen B. Acyclovir, herpes, and pregnancy [letter]. Lancet. 1990;336.
62 Eldridge R, Andrews E, Tilson H, et al. Pregnancy outcomes following systemic prenatal acyclovir exposure—June 1, 1984-June 30, 1993. MMWR. 1993;42:806-809. [pmid: 8413168].
63 Centers for Disease Control. Sexually transmitted diseases: treatment guidelines. Atlanta: Centers for Disease Control. 1989:14-16.
64 American College of Obstetricians and Gynecologists. Perinatal herpes simplex virus infections. Technical Bulletin no. 122. Washington, DC. Washington, DC. 1988:1-5. [pmcid: 442465].
65 American Academy of Pediatrics Herpes simplexIn: Peter G, ed. 1994 Red Book: report of the Committee on Infectious Diseases. 23rd ed. , Elk Grove Village, IL:American Academy of Pediatrics,1994 242 252 325177
66 Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical preventive health care. Ottawa: Canada Communication Group. 1994:108-115.
67 Prober CG, Corey L, Brown ZA, et al. The management of pregnancies complicated by genital infections with herpes simplex virus. Clin Infect Dis. 1992;15:1031-1038. [pmid: 1457634].
68 Libman MD, Dascal A, Kramer MS, et al. Strategies for the prevention of neonatal infection with herpes simplex virus: a decision analysis. Rev Infect Dis. 1991;13:1093-1104. [pmid: 1663650].