# SCREENING

1 Screening for Asymptomatic Coronary Artery Disease

2 Screening for High Blood Cholesterol and Other Lipid Abnormalities

3 Screening for Hypertension

4 Screening for Asymptomatic Carotid Artery Stenosis

5 Screening for Peripheral Arterial Disease

6 Screening for Abdominal Aortic Aneurysm

7 Screening for Breast Cancer

8 Screening for Colorectal Cancer

9 Screening for Cervical Cancer

10 Screening for Prostate Cancer

11 Screening for Lung Cancer

12 Screening for Skin Cancer— Including Counseling to Prevent Skin Cancer

13 Screening for Testicular Cancer

14 Screening for Ovarian Cancer

15 Screening for Pancreatic Cancer

16 Screening for Oral Cancer

17 Screening for Bladder Cancer

18 Screening for Thyroid Cancer

19 Screening for Diabetes Mellitus

20 Screening for Thyroid Disease

21 Screening for Obesity

22 Screening for Iron Deficiency Anemia— Including Iron Prophylaxis

23 Screening for Elevated Lead Levels in Childhood and Pregnancy

24 Screening for Hepatitis B Virus Infection

25 Screening for Tuberculous Infection-- Including Bacille Calmette-Guérin Immunization

26 Screening for Syphilis

27 Screening for Gonorrhea— Including Ocular Prophylaxis in Newborns

28 Screening for Human Immunodeficiency Virus Infection

29 Screening for Chlamydial Infection— Including Ocular Prophylaxis in Newborns

30 Screening for Genital Herpes Simplex

31 Screening for Asymptomatic Bacteriuria

32 Screening for Rubella— Including Immunization of Adolescents and Adults

33 Screening for Visual Impairment

34 Screening for Glaucoma

35 Screening for Hearing Impairment

36 Screening Ultrasonography in Pregnancy

37 Screening for Preeclampsia

38 Screening for D (Rh) Incompatibility

39 Intrapartum Electronic Fetal Monitoring

40 Home Uterine Activity Monitoring

41 Screening for Down Syndrome

42 Screening for Neural Tube Defects— Including Folic Acid/Folate Prophylaxis

43 Screening for Hemoglobinopathies

44 Screening for Phenylketonuria

45 Screening for Congenital Hypothyroidism

46 Screening for Postmenopausal Osteoporosis

47 Screening for Adolescent Idiopathic Scoliosis

48 Screening for Dementia

49 Screening for Depression

50 Screening for Suicide Risk

51 Screening for Family Violence

52 Screening for Problem Drinking

53 Screening for Drug Abuse