# The Periodic Health Examination: Age-Specific Charts

The periodic health visit is an important opportunity for the delivery of clinical preventive services. Identification of specific preventive services that are appropriate for inclusion in the periodic health examination has been one of the principal objectives of the U.S. Preventive Services Task Force project. The process by which these determinations were made is discussed in detail in Chapter ii. This chapter explores the services that were evaluated by the Task Force and are recommended as part of the periodic health examination of the asymptomatic individual. It includes a series of five tables listing specific preventive services that are recommended for patients in different age groups. Conditions that are likely to benefit from early identification but that are not considered appropriate for routine screening are listed in Table 6. Disorders appearing in this table are often overlooked by clinicians due to failure to recognize suggestive signs or symptoms. For example, child abuse may not be diagnosed if physical findings suggestive of abuse are overlooked during routine or symptomatic examinations.^ 1 ^

Table 6. Conditions for Which Clinicians Should Remain Alert

Condition | Population | Chapter
Symptoms of peripheral arterial disease | Older persons, smokers, diabetic persons | 5
Skin lesions with malignant features | General population, particularly those with established risk factors | 12
Symptoms and signs of oral cancer and premalignancy | Persons who use tobacco, older persons who drink alcohol regularly | 16
Subtle or nonspecific symptoms and signs of thyroid dysfunction | Older persons, postpartum women, persons with Down syndrome | 20
Signs of ocular misalignment | Infants and children | 33
Symptoms and signs of hearing impairment | Infants and young children (<3 yr) | 35
Large spinal curvatures | Adolescents | 47
Changes in functional performance | Older persons | 48
Depressive symptoms | Adolescents, young adults, persons at increased risk for depression | 49
Evidence of suicidal ideation factors for suicide | Persons with established risk | 50
Various presentations of family violence | General population | 51
Symptoms and signs of drug abuse | General population | 53
Obvious signs of untreated tooth decay or mottling, inflamed or cyanotic gingiva, loose teeth, and severe halitosis | General population | 61
Evidence of early childhood caries, mismatching of upper and lower dental arches, dental crowding or malalignment, premature loss of primary posterior teeth (baby molars) and obvious mouth breathing | Children | 61

The Task Force judged it especially important to emphasize those preventive services that have been proven to be effective in properly conducted studies, and to tailor the content of the periodic health examination to the individual needs of the patient. This approach is based on the recognition that the limited time afforded to patient encounters may be most constructively used if the clinician focuses on interventions of proven efficacy. The clinician can then choose from among these effective interventions for each patient according to the likeliest causes of illness and injury based on that individual's age, sex, and other risk factors. Thus, the two most important factors to consider are the potential effectiveness of clinical interventions in improving clinical outcomes and the leading causes of mortality and morbidity.

Clinical efforts directed toward promoting health and preventing disease are of limited value if the preventive intervention does not improve outcome. Thus, the major consideration in setting priorities is effectiveness of the intervention. Although suicide and homicide are important causes of death among adolescents, for example, the effectiveness of efforts by primary care clinicians to prevent deaths from intentional injuries has not been established (see Chapters 50 and 59). On the other hand, there are effective measures to reduce the risk of motor vehicle injuries, a leading cause of death in this age group. Proper use of safety belts has been shown to reduce the risk of injury and death from motor vehicle crashes by as much as 40-60%.^2-5^ Alcohol intoxication is associated with nearly half of all fatal crashes.^ 6 ^ With one of three deaths among young persons occurring in motor vehicle crashes,^ 7 ^ the busy clinician seeing adolescent patients is best advised to direct attention to the use of safety belts and the dangers of driving while under the influence of alcohol, rather than to interventions of unproven effectiveness. For each recommendation in Tables 1- 5, the reader is urged to refer to appropriate chapters in the text to obtain detailed information about the scientific rationale.

It is also important to consider the leading causes of morbidity and mortality for patients when establishing priorities for the periodic health examination. For example, a clinician wishing to practice prevention during the few remaining minutes of an office visit with a 56-year-old female might consider a number of different counseling interventions that are effective in changing behavior, such as counseling about reducing dietary fat or avoiding high-risk sexual behavior. A 56-year-old female is considerably more likely to die from cardiac disease than from HIV or other sexually transmitted diseases. For women age 55-64 years in the U.S. during 1993, the death rate due to heart disease was 204/100,000, making it the second leading cause of death. HIV, on the other hand, is not even among the 10 leading causes of death for women of that age group.^ 7 ^ It seems clear on the basis of mortality data alone that a few minutes with such a patient might be more productively spent by discussing dietary fat. Leading causes of death by age group are provided for each table.

While more difficult to measure than mortality, leading causes of morbidity also should guide the use of preventive services. The adolescent population provides a clear example. Over 60% of gonococcal infections occur in persons under age 25.^ 8 ^ The prevalence of chlamydial infection is highest among young women age 15-19.^ 9 ^ Each year in the U.S., about 1 million adolescent females aged 15-19 (about 8-10% of this age group) and nearly 30,000 girls under age 15 become pregnant.^ 10 ^ Thus, encounters with the adolescent population should target unintended pregnancy and sexually transmitted diseases as important causes of morbidity in this age group. Essential hypertension, neoplasms, and problem drinking account for a large number of office and outpatient department visits in older patients,^11-13^ while injuries and poisonings account for 32% of emergency room visits among the general population.^ 14 ^ Among elderly patients, commonly reported causes of chronic morbidity include visual and hearing impairments.^ 11 ^

Individual risk factors are also important to consider in designing the periodic health examination. The leading causes of morbidity and mortality may differ considerably for persons in special high-risk groups as compared to individuals of the same age and sex in the general population. For example, minority children in central cities are 6 times as likely as non-urban non-minority children to have elevated blood lead levels.^ 15 ^ Therefore, periodic health examinations for members of this high-risk population should include activities to prevent lead exposure, including screening. Injection drug use is also uncommon in the general population, but among individuals with this history, acquired immunodeficiency syndrome (AIDS) is the leading cause of death^ 16 ^ and hepatitis B is an important cause of morbidity and mortality. Thus, essential preventive interventions in the periodic health examination of an injection drug user are counseling about measures to prevent transmission of HIV and other infectious diseases and immunization against hepatitis B virus. The differences in priorities among individuals in different age groups and risk categories and the varying effectiveness of some preventive services in different populations make it impossible to recommend a uniform periodic health examination for all persons.

Many of the preventive services appearing in Tables 1- 5 are recommended only for members of high-risk groups. These are listed separately in the lower half of each table and are grouped by general patient characteristics that broadly define high-risk populations. This organization will help the clinician to identify patients who might be eligible for one or more of the interventions listed. It is crucial, however, to then read the specific high-risk definition indicated by an annotated high-risk (HR) code after each intervention, because patients may share characteristics of the general high-risk grouping without actually meeting the individual high-risk definitions for every intervention within that group. For example, a 23-year-old woman whose high-risk sexual behavior is limited to having two recent sexual partners should be screened for gonorrhea and chlamydia infection, but she may not require screening for syphilis or a hepatitis A vaccine. To avoid providing unnecessary preventive services, clinicians must evaluate carefully whether patients who are potentially at risk meet the specific high-risk definitions for each potential intervention. While nonstandardized historical questions were not evaluated by the Task Force and therefore are not included in the tables, the history and physical examination can be used to identify high-risk individuals who would benefit from targeted interventions. Appropriate chapters in the text provide more detailed guidelines to help identify individuals at increased risk.

Task Force recommendations can be compared with those of other major organizations and government agencies, which are listed in each chapter under the heading Recommendations of Other Groups. In addition, the Clinical Interventionsection contains detailed recommendations and, in many cases, concise information for the clinician on: conditions to remain alert for, anticipatory guidance, currently recommended techniques, drug dosages, and other specifics for performing recommended preventive services. It is not the intent of the Guideto supply comprehensive information on how to provide these preventive services. The interested reader is referred to the U.S. Public Health Service's prevention implementation program, "Put Prevention Into Practice,"^ 17 ^ and to other published sources on the implementation of clinical preventive services.^ 18 ^

The preventive services examined in this report and appearing in Tables 1- 5 include only those preventive services that might be performed by primary care clinicians on asymptomatic persons in the context of routinehealth care (see Chapter ii). Preventive measures involving persons with signs or symptoms and those performed outside the clinical setting are not within the scope of this report or its recommendations. While the Task Force did not evaluate all components of the physical examination, several specific screening maneuvers that might be performed as part of the physical examination are included if they were considered. The tables are not intended as a complete list of all that should occur during the periodic health examination. Rather, these recommendations encompass those preventive services that have been examined by the Task Force and that have been shown to have satisfactory evidence of clinical effectiveness, based on the methodology discussed in the preceding chapter.

At the same time, the preventive interventions listed are not exhaustive. The periodic health examination performed by most pediatricians, for example, includes a number of maneuvers that were not examined by the Task Force, such as screening for developmental disorders and anticipatory guidance the interested reader can refer to the recommendations of other groups for further information on such topics.^19-21^ Similarly, Task Force recommendations relating to preventive services during pregnancy should not be interpreted as comprehensive guidelines for prenatal care.

Preventive services listed in each table are not necessarily recommended at every periodic visit. For example, although sigmoidoscopy is recommended for persons age 50 and over, it is not recommended annually even though periodic visits in this age group may occur once a year. Where a specific periodicity has been proven effective (e.g., annual fecal occult blood testing in persons 50 years of age and over), this information is included in the footnotes for each table. The Task Force has not attempted to design a periodicity schedule for health supervision visits because for many interventions, evidence of an optimal periodicity is lacking. In addition, periodicity for certain interventions varies with patient characteristics (age, gender, risk factors).

Although the preventive services listed in Tables 1- 5 can serve as the basis for designing periodic checkups devoted entirely to health promotion and disease prevention, they may also be performed during visits for other reasons (e.g., illness visits, chronic disease checkups) when indicated. Health maintenance needs to be considered at every visit. For patients with limited access to care, the illness visit may provide the only realistic opportunity to discuss prevention. It is recognized that busy clinicians may not be able to perform all recommended preventive services during a single clinical encounter. Indeed, it is not clear that such a grouping is either necessary or clinically effective. If a sparser, evidence-based protocol is used, health maintenance can frequently be done during acute visits. Patients suffering from an acute illness or injury, however, may not be receptive to some preventive interventions. The clinician must therefore use discretion in selecting appropriate preventive services from these tables and may wish to give special emphasis to those effective interventions aimed at the leading causes of illness and disability in the age group. Recommended preventive services that cannot be performed by the clinician at the current visit should be scheduled for a later health visit.

Immunizations appearing in Tables 1-5 are those recommended on a routine basis and do not apply to persons with special exposures to infected individuals. The reader is referred to Chapter 67 for detailed guidelines on immunizations in such circumstances.

Tables 1- 5do not include interventions for which the Task Force found insufficient evidence on which to base recommendations for or against inclusion in the periodic health examination (i.e., "C" recommendations). The Task Force recognizes that there may be other grounds on which to base a recommendation for or against an intervention when scientific evidence is not available, including patient preference, costs associated with the procedure, the likelihood of benefit or harms from the procedure, and the burden of suffering from the condition. Consideration of these other grounds can guide the clinician in making decisions about the appropriate use of these interventions. The reader is referred to Chapter ii for detailed discussion of the development of "C" recommendations. For many important causes of morbidity and mortality, evidence of effective preventive interventions is lacking. There is a great need for well-controlled, randomized studies with adequate sample sizes to evaluate the effectiveness of preventive interventions for many conditions. Such topics merit attention in the planning of future research agendas.

The draft update of this chapter was prepared for the U.S. Preventive Services Task Force by Ann O'Malley, MD, MPH, and Carolyn DiGuiseppi, MD, MPH.

Table 1. Birth to 10 Years

Table 1. Birth to 10 Years

Interventions Considered and Recommended for the Periodic Health Examination | Leading Causes of Death; - Conditions originating in perinatal period; - Congenital anomalies; - Sudden infant death syndrome (SIDS); - Unintentional injuries (non-motor vehicle); - Motor vehicle injuries
Interventions for the General Population
SCREENING | Limit fat & cholesterol, maintain caloric balance, emphasize grains, fruits, vegetables (age >=2 yr) [Ch 56]
Height and weight [Ch 21] | Regular physical activity * [Ch 55 ]
Blood pressure [Ch 3]
Vision screen (age 3-4 yr) [Ch 33]
Hemoglobinopathy screen (birth)[1] [Ch 43 ]
Phenylalanine level (birth)[2] [Ch 44 ] | Substance Use [Ch 54 ]
T _4 _ and/or TSH (birth)[3] [Ch 45] | Effects of passive smoking *
COUNSELING | Anti-tobacco message *
Injury Prevention [ Ch 57, 58 ] | Dental Health [Ch 61]
Child safety car seats (age <5 yr) | Regular visits to dental care providera
Lap-shoulder belts (age >=5 yr) | Floss, brush with fluoride toothpaste dailya
Bicycle helmet, avoid bicycling near traffic | Advice about baby bottle tooth decay[*]
Smoke detector, flame retardant sleepwear | IMMUNIZATIONS [Ch 65]
Hot water heater temperature <120-130 degrees F | Diphtheria-tetanus-pertussis (DTP)[4]
Window/stair guards, pool fence | Oral poliovirus (OPV)[5]
Safe storage of drugs, toxic substances, firearms, & matches | Measles-mumps-rubella (MMR)[6]
Syrup of ipecac, poison control phone number | H. influenzae type b (Hib) conjugate [7]
CPR training for parents/caretakers | Hepatitis B [8]
Diet and Exercise | Varicella [9]
Breast-feeding, iron-enriched formula and foods (infants & toddlers) [ Ch 22, 56 ] | CHEMOPROPHYLAXIS Ocular prophylaxis (birth) [Ch 27]
Interventions for High-Risk Populations
POPULATION | POTENTIAL INTERVENTIONS (See detailed high-risk definitions)
Preterm or low birth weight | Hemoglobin/hematocrit (HR1)
Infants of mothers at risk for HIV | HIV testing (HR2)
Low income immigrants | Hemoglobin/hematocrit (HR1) PPD (HR3)
TB contacts | PPD (HR3)
Native American/Alaska Native | Hemoglobin/hematocrit (HR1) PPD (HR3) hepatitis A vaccine (HR4) pneumococcal vaccine (HR5)
Travelers to developing countries | Hepatitis A vaccine (HR4)
Residents of long-term care facilities | PPD (HR3) hepatitis A vaccine (HR4) influenza vaccine (HR6)
Certain chronic medical conditions | PPD (HR3) pneumococcal vaccine (HR5) influenza vaccine (HR6)
Increased individual or community lead exposure | Blood lead level (HR7)
Inadequate water fluoridation | Daily fluoride supplement (HR8)
Family h/o skin cancer nevi fair skin, eyes, hair | Avoid excess/midday sun, use protective clothing* (HR9)

[1] Whether screening should be universal or targeted to high-risk groups will depend on the proportion of high-risk individuals in the screening area, and other considerations (see Ch. 43. [2] If done during first 24 hr of life, repeat by age 2 wk. [3] Optimally between day 2 and 6, but in all cases before newborn nursery discharge. [4] 2, 4, 6, and 12-18 mo once between ages 4-6 yr (DTaP may be used at 15 mo and older). [5] 2, 4, 6-18 mo once between ages 4-6 yr. [6] 12-15 mo and 4-6 yr. [7] 2, 4, 6 and 12-15 mo no dose needed at 6 mo if PRP-OMP vaccine is used for first 2 doses. [8] Birth, 1 mo, 6 mo or, 0-2 mo, 1-2 mo later, and 6-18 mo. If not done in infancy: current visit, and 1 and 6 mo later. [9] 12-18 mo or older child without hx of chickenpox or previous immunization. Include information on risk in adulthood, duration of immunity, and potential need for booster doses. [*] The ability of clinician counseling to influence this behavior is unproven.

- HR1 =
- Infants age 6-12 mo who are: living in poverty, black, Native American or Alaska Native, immigrants from developing countries, preterm or low birth weight infants, or infants whose principal dietary intake is unfortified cow's milk (see Ch. 22).
- HR2 =
- Infants born to high-risk mothers whose HIV status is unknown. Women at high risk include: past or present injection drug use persons who exchange sex for money or drugs, and their sex partners injection drug-using, bisexual, or HIV-positive sex partners currently or in past persons seeking treatment for STDs blood transfusion during 1978-1985 (see Ch. 28).
- HR3 =
- Persons infected with HIV, close contacts of persons with known or suspected TB, persons with medical risk factors associated with TB, immigrants from countries with high TB prevalence, medically underserved low-income populations (including homeless), residents of long-term care facilities (see Ch. 25). See Ch. 25 for indications for BCG vaccine.
- HR4 =
- Persons >=2 yr living in or traveling to areas where the disease is endemic and where periodic outbreaks occur (e.g., countries with high or intermediate endemicity certain Alaska Native, Pacific Island, Native American, and religious communities). Consider for institutionalized children aged >=2 yr. Clinicians should also consider local epidemiology (see Ch. 65-67).
- HR5 =
- Immunocompetent persons >=2 yr with certain medical conditions, including chronic cardiac or pulmonary disease, diabetes mellitus, and anatomic asplenia. Immunocompetent persons >=2 yr living in high-risk environments or social settings (e.g., certain Native American and Alaska Native populations) (see Ch. 66).
- HR6 =
- Annual vaccination of children >=6 mo who are residents of chronic care facilities or who have chronic cardiopulmonary disorders, metabolic diseases (including diabetes mellitus), hemoglobinopathies, immunosuppression, or renal dysfunction (see Ch. 66). See Ch. 66 for indications for amantadine/rimantadine prophylaxis.
- HR7 =
- Children about age 12 mo who: 1) live in communities in which the prevalence of lead levels requiring individual intervention, including residential lead hazard control or chelation, is high or undefined 2) live in or frequently visit a home built before 1950 with dilapidated paint or with recent or ongoing renovation or remodeling 3) have close contact with a person who has an elevated lead level 4) live near lead industry or heavy traffic 5) live with someone whose job or hobby involves lead exposure 6) use lead-based pottery or 7) take traditional ethnic remedies that contain lead (see Ch. 23).
- HR8 =
- Children living in areas with inadequate water fluoridation (<0.6 ppm) (see Ch. 61).
- HR9 =
- Persons with a family history of skin cancer, a large number of moles, atypical moles, poor tanning ability, or light skin, hair, and eye color (see Ch. 12).

Table 2. Ages 11-24 Years

Table 2. Ages 11-24 Years

Interventions Considered and Recommended for the Periodic Health Examination | Leading Causes of Death; - Motor vehicle/other unintentional injuries; - Homicide; - Suicide; - Malignant neoplasms; - Heart diseases
Interventions for the General Population
SCREENING | Unintended pregnancy: contraception
Height & weight [Ch 21] | Diet and Exercise
Blood pressure [1] [Ch 3] | Limit fat & cholesterol maintain caloric balance emphasize grains, fruits, vegetables [Ch 56]
Papanicolaou (Pap) test [2] (females) [Ch 9] | Adequate calcium intake (females) [Ch 56]
Chlamydia screen [3] (females <20 yr) [Ch 29] | Regular physical activity[*] [Ch 55]
Rubella serology or vaccination hx [4] (females >12 yr) [Ch 32] | Dental Health [Ch 61]
Assess for problem drinking [Ch 52] | Regular visits to dental care providera
COUNSELING | Floss, brush with fluoride toothpaste dailya
Injury Prevention [ Ch 57, 58 ] | IMMUNIZATIONS [ Ch 65, 66 ]
Lap/shoulder belts | Tetanus-diphtheria (Td) boosters (11-16 yr)
Bicycle/motorcycle/ATV helmets [*] | Hepatitis B [5]
Smoke detector[*] | MMR (11-12 yr)[6]
Safe storage/removal of firearms[*] [ Ch 50, 59 ] | Varicella (11-12 yr)[7]
Substance Use | Rubella [4] (females >12 yr) [Ch 32]
Avoid tobacco use [Ch 54] | CHEMOPROPHYLAXIS
Avoid underage drinking & illicit drug use[*][ Ch 52, 53 ] | Multivitamin with folic acid (females planning/capable of pregnancy) [Ch 42]
Avoid alcohol/drug use while driving, swimming, boating, etc. [*] [ Ch 57, 58 ]
Sexual Behavior [ Ch 62, 63 ]
STD prevention: abstinence[*] avoid high-risk behavior[*] condoms/female barrier with spermicide[*]
Interventions for High-Risk Populations
POPULATION | POTENTIAL INTERVENTIONS (See detailed high-risk definitions)
High-risk sexual behavior | RPR/VDRL (HR1) screen for gonorrhea (female) (HR2), HIV (HR3), chlamydia (female) (HR4) hepatitis A vaccine (HR5)
Injection or street drug use | RPR/VDRL (HR1) HIV screen (HR3) hepatitis A vaccine (HR5) PPD (HR6) advice to reduce infection risk (HR7)
TB contacts immigrants low income | PPD (HR6)
Native Americans/Alaska Natives | Hepatitis A vaccine (HR5) PPD (HR6) pneumococcal vaccine (HR8)
Travelers to developing countries | Hepatitis A vaccine (HR5)
Certain chronic medical conditions | PPD (HR6) pneumococcal vaccine (HR8) influenza vaccine (HR9)
Settings where adolescents and young adults congregate | Second MMR (HR10)
Susceptible to varicella, measles, mumps | Varicella vaccine (HR11) MMR (HR12)
Blood transfusion between 1978-1985 | HIV screen (HR3)
Institutionalized persons health care/lab workers | Hepatitis A vaccine (HR5) PPD (HR6) influenza vaccine (HR9)
Family h/o skin cancer nevi fair skin, eyes, hair | Avoid excess/midday sun, use protective clothing* (HR13)
Prior pregnancy with neural tube defect | Folic acid 4.0 mg (HR14)
Inadequate water fluoridation | Daily fluoride supplement (HR15)

[1]Periodic BP for persons aged >=21 yr. [2] If sexually active at present or in the past: q <= 3 yr. If sexual history is unreliable, begin Pap tests at age 18 yr. [3] If sexually active. [4] Serologic testing, documented vaccination history, and routine vaccination against rubella (preferably with MMR) are equally acceptable alternatives. [5] If not previously immunized: current visit, 1 and 6 mo later. [6] If no previous second dose of MMR. [7] If susceptible to chickenpox. [*] The ability of clinician counseling to influence this behavior is unproven.

- HR1 =
- Persons who exchange sex for money or drugs, and their sex partners persons with other STDs (including HIV) and sexual contacts of persons with active syphilis. Clinicians should also consider local epidemiology (see Ch. 26).
- HR2 =
- Females who have: two or more sex partners in the last year a sex partner with multiple sexual contacts exchanged sex for money or drugs or a history of repeated episodes of gonorrhea. Clinicians should also consider local epidemiology (see Ch. 27).
- HR3 =
- Males who had sex with males after 1975 past or present injection drug use persons who exchange sex for money or drugs, and their sex partners injection drug-using, bisexual, or HIV-positive sex partner currently or in the past blood transfusion during 1978-1985 persons seeking treatment for STDs. Clinicians should also consider local epidemiology (see Ch. 28).
- HR4 =
- Sexually active females with multiple risk factors including: history of prior STD new or multiple sex partners age under 25 nonuse or inconsistent use of barrier contraceptives cervical ectopy. Clinicians should consider local epidemiology of the disease in identifying other high-risk groups (see Ch. 29).
- HR5 =
- Persons living in, traveling to, or working in areas where the disease is endemic and where periodic outbreaks occur (e.g., countries with high or intermediate endemicity certain Alaska Native, Pacific Island, Native American, and religious communities) men who have sex with men injection or street drug users. Vaccine may be considered for institutionalized persons and workers in these institutions, military personnel, and day-care, hospital, and laboratory workers. Clinicians should also consider local epidemiology (see Ch. 66,67).
- HR6 =
- HIV positive, close contacts of persons with known or suspected TB, health care workers, persons with medical risk factors associated with TB, immigrants from countries with high TB prevalence, medically underserved low-income populations (including homeless), alcoholics, injection drug users, and residents of long-term care facilities (see Ch. 25). See Ch. 25 for indications for BCG vaccine.
- HR7 =
- Persons who continue to inject drugs (see Ch. 53).
- HR8 =
- Immunocompetent persons with certain medical conditions, including chronic cardiac or pulmonary disease, diabetes mellitus, and anatomic asplenia. Immunocompetent persons who live in high-risk environments or social settings (e.g., certain Native American and Alaska Native populations) (see Ch. 66).
- HR9 =
- Annual vaccination of: residents of chronic care facilities persons with chronic cardiopulmonary disorders, metabolic diseases (including diabetes mellitus), hemoglobinopathies, immunosuppression, or renal dysfunction and health care providers for high-risk patients (see Ch. 66). See Ch. 66 for indications for amantadine/rimantadine prophylaxis.
- HR10 =
- Adolescents and young adults in settings where such individuals congregate (e.g., high schools and colleges), if they have not previously received a second dose (see Ch. 65, 66).
- HR11 =
- Healthy persons aged >=13 yr without a history of chickenpox or previous immunization. Consider serologic testing for presumed susceptible persons aged >=13 yr (see Ch. 65, 66).
- HR12 =
- Persons born after 1956 who lack evidence of immunity to measles or mumps (e.g., documented receipt of live vaccine on or after the first birthday, laboratory evidence of immunity, or a history of physician-diagnosed measles or mumps) (see Ch. 65, 66).
- HR13 =
- Persons with a family or personal history of skin cancer, a large number of moles, atypical moles, poor tanning ability, or light skin, hair, and eye color (see Ch. 12).
- HR14 =
- Women with prior pregnancy affected by neural tube defect who are planning pregnancy (see Ch. 42).
- HR15 =
- Persons aged <17 yr living in areas with inadequate water fluoridation (<0.6 ppm) (see Ch. 61).

Table 3. Ages 25-64 Years

Table 3. Ages 25-64 Years

Interventions Considered and Recommended for the Periodic Health Examination | Leading Causes of Death; - Malignant neoplasms; - Heart diseases; - Motor vehicle and other unintentional injuries; - Human immunodeficiency virus (HIV) infection; - Suicide and homicide
Interventions for the General Population
SCREENING | Regular physical activity[*] [Ch 55]
Blood pressure [Ch 3] | Injury Prevention [Ch 57,58]
Height and weight [Ch 21] | Lap/shoulder belts
Total blood cholesterol (men ages 35-65, women ages 45-65) [Ch 2] | Motorcycle/bicycle/ATV helmetsa
Papanicolaou (Pap) test (women) [1] [Ch 9] | Smoke detector*
Fecal occult blood test [2] and/or sigmoidoscopy (>=50 yr) [Ch 8] | Safe storage/removal of firearms[*] [Ch 50,59]
Mammogram +/- clinical breast exam [3] (women 50-69 yr) [Ch 7] | Sexual Behavior [Ch 62,63]
Assess for problem drinking [Ch 52] | STD prevention: avoid high-risk behavior* condoms/female barrier with spermicide*
Rubella serology or vaccination hx [4] (women of childbearing age) [Ch 32] | Unintended pregnancy: contraception
COUNSELING | Dental Health [Ch 61]
Substance Use | Regular visits to dental care providera
Tobacco cessation [Ch 54] | Floss, brush with fluoride toothpaste daily[*]
Avoid alcohol/drug use while driving, swimming, boating, etc.a [Ch 57,58] | IMMUNIZATIONS [Ch 32,66]
Diet and Exercise
Limit fat & cholesterol maintain caloric balance emphasize grains, fruits, vegetables [Ch 56] | Tetanus-diphtheria (Td) boosters
Adequate calcium intake (women) [Ch 56] | Rubella [4] (women of childbearing age)
| CHEMOPROPHYLAXIS
| Multivitamin with folic acid (women planning or capable of pregnancy) [Ch 42]
| Discuss hormone prophylaxis (peri- and postmenopausal women) [Ch 68]
Interventions for High-Risk Populations
POPULATION | POTENTIAL INTERVENTIONS (See detailed high-risk definitions)
High-risk sexual behavior | RPR/VDRL (HR1) screen for gonorrhea (female) (HR2), HIV (HR3), chlamydia (female) (HR4) hepatitis B vaccine (HR5) hepatitis A vaccine (HR6)
Injection or street drug use | RPR/VDRL (HR1) HIV screen (HR3) hepatitis B vaccine (HR5) hepatitis A vaccine (HR6) PPD (HR7) advice to reduce infection risk (HR8)
Low income TB contacts immigrants alcoholics | PPD (HR7)
Native Americans/Alaska Natives | Hepatitis A vaccine (HR6) PPD (HR7) pneumococcal vaccine (HR9)
Travelers to developing countries | Hepatitis B vaccine (HR5) hepatitis A vaccine (HR6)
Certain chronic medical conditions | PPD (HR7) pneumococcal vaccine (HR9) influenza vaccine (HR10)
Blood product recipients | HIV screen (HR3) hepatitis B vaccine (HR5)
Susceptible to measles, mumps, or varicella | MMR (HR11) varicella vaccine (HR12)
Institutionalized persons | Hepatitis A vaccine (HR6) PPD (HR7) pneumococcal vaccine (HR9) influenza vaccine (HR10)
Health care/lab workers | Hepatitis B vaccine (HR5) hepatitis A vaccine (HR6) PPD (HR7) influenza vaccine (HR10)
Family h/o skin cancer fair skin, eyes, hair | Avoid excess/midday sun, use protective clothing[*](HR13)
Previous pregnancy with neural tube defect | Folic acid 4.0 mg (HR14)

[1] Women who are or have been sexually active and who have a cervix: q <= 3 yr. [2] Annually. [3] Mammogram q1-2 yr, or mammogram q1-2 yr with annual clinical breast examination. [4] Serologic testing, documented vaccination history, and routine vaccination (preferably with MMR) are equally acceptable alternatives. [*] The ability of clinician counseling to influence this behavior is unproven.

- HR1 =
- Persons who exchange sex for money or drugs, and their sex partners persons with other STDs (including HIV) and sexual contacts of persons with active syphilis. Clinicians should also consider local epidemiology (see Ch. 26).
- HR2 =
- Women who exchange sex for money or drugs, or who have had repeated episodes of gonorrhea. Clinicians should also consider local epidemiology (see Ch. 27).
- HR3 =
- Men who had sex with men after 1975 past or present injection drug use persons who exchange sex for money or drugs, and their sex partners injection drug-using, bisexual, or HIV-positive sex partner currently or in the past blood transfusion during 1978-1985 persons seeking treatment for STDs. Clinicians should also consider local epidemiology (see Ch. 28).
- HR4 =
- Sexually active women with multiple risk factors including: history of STD new or multiple sex partners nonuse or inconsistent use of barrier contraceptives cervical ectopy. Clinicians should also consider local epidemiology (see Ch. 29).
- HR5 =
- Blood product recipients (including hemodialysis patients), persons with frequent occupational exposure to blood or blood products, men who have sex with men, injection drug users and their sex partners, persons with multiple recent sex partners, persons with other STDs (including HIV), travelers to countries with endemic hepatitis B (see Ch. 66).
- HR6 =
- Persons living in, traveling to, or working in areas where the disease is endemic and where periodic outbreaks occur (e.g., countries with high or intermediate endemicity certain Alaska Native, Pacific Island, Native American, and religious communities) men who have sex with men injection or street drug users. Consider for institutionalized persons and workers in these institutions, military personnel, and day-care, hospital, and laboratory workers. Clinicians should also consider local epidemiology (see Ch. 66, 67).
- HR7 =
- HIV positive, close contacts of persons with known or suspected TB, health care workers, persons with medical risk factors associated with TB, immigrants from countries with high TB prevalence, medically underserved low-income populations (including homeless), alcoholics, injection drug users, and residents of long-term care facilities (see Ch. 25). See Ch. 25 for indications for BCG vaccine.
- HR8 =
- Persons who continue to inject drugs (see Ch. 53).
- HR9 =
- Immunocompetent institutionalized persons aged >=50 yr and immunocompetent persons with certain medical conditions, including chronic cardiac or pulmonary disease, diabetes mellitus, and anatomic asplenia. Immunocompetent persons who live in high-risk environments or social settings (e.g., certain Native American and Alaska Native populations) (see Ch. 66).
- HR10 =
- Annual vaccination of residents of chronic care facilities persons with chronic cardiopulmonary disorders, metabolic diseases (including diabetes mellitus), hemoglobinopathies, immunosuppression, or renal dysfunction and health care providers for high-risk patients (Ch. 66). See Ch. 66 for indications for amantadine/rimantadine prophylaxis.
- HR11 =
- Persons born after 1956 who lack evidence of immunity to measles or mumps (e.g., documented receipt of live vaccine on or after the first birthday, laboratory evidence of immunity, or a history of physician-diagnosed measles or mumps) (see Ch. 66).
- HR12 =
- Healthy adults without a history of chickenpox or previous immunization. Consider serologic testing for presumed susceptible adults (see Ch. 65, 66).
- HR13 =
- Persons with a family or personal history of skin cancer, a large number of moles, atypical moles, poor tanning ability, or light skin, hair, and eye color (see Ch. 12).
- HR14 =
- Women with previous pregnancy affected by neural tube defect who are planning pregnancy (see Ch. 42).

Table 4. Age 65 and Older

Table 4. Age 65 and Older

Interventions Considered and Recommended for the Periodic Health Examination | Leading Causes of Death; - Heart diseases; - Malignant neoplasms (lung, colorectal, breast); - Cerebrovascular disease; - Chronic obstructive pulmonary disease; - Pneumonia and influenza
Interventions for the General Population
SCREENING | Injury Prevention [Ch 57,58]
Blood pressure [Ch 3] | Lap/shoulder belts
Height and weight [Ch 21] | Motorcycle and bicycle helmetsa
Fecal occult blood test [1] and/or sigmoidoscopy [Ch 8] | Fall prevention[*]Safe storage/removal of firearms[*] [Ch 50,59]
Mammogram +/- clinical breast exam [2] (women <=69 yr) [Ch 7] | Smoke detector[*]
Papanicolaou (Pap) test (women)[3] [Ch 9] | Set hot water heater to <120-130 degrees F[*]
Vision screening [Ch 33] | CPR training for household members
Assess for hearing impairment [Ch 35] | Dental Health [Ch 61]
Assess for problem drinking [Ch 52] | Regular visits to dental care provider[*]
COUNSELING | Floss, brush with fluoride toothpaste daily[*]
Substance Use | Sexual Behavior
Tobacco cessation [Ch 54] | STD prevention: avoid high-risk sexual behavior* use condoms[*] [Ch 62]
Avoid alcohol/drug use while driving, swimming, boating, etc.[*] [Ch 57,58] | IMMUNIZATIONS [Ch 66]
Diet and Exercise | Pneumococcal vaccine
Limit fat & cholesterol maintain caloric balance emphasize grains, fruits, vegetables [Ch 56] | Influenza [1]
Adequate calcium intake (women) [Ch 56] | Tetanus-diphtheria (Td) boosters
Regular physical activity[*] [Ch 55,58] | CHEMOPROPHYLAXIS
| Discuss hormone prophylaxis (women) [Ch 68]
Interventions for High-Risk Populations
POPULATION | POTENTIAL INTERVENTIONS (See detailed high-risk definitions)
Institutionalized persons | PPD (HR1) hepatitis A vaccine (HR2) amantadine/rimantadine (HR4)
Chronic medical conditions TB contacts low income immigrants alcoholics | PPD (HR1)
Persons >=75 yr or >=70 yr with risk factors for falls | Fall prevention intervention (HR5)
Cardiovascular disease risk factors | Consider cholesterol screening (HR6)
Family h/o skin cancer nevi fair skin, eyes, hair | Avoid excess/midday sun, use protective clothing[*](HR7)
Native Americans/Alaska Natives | PPD (HR1) hepatitis A vaccine (HR2)0
Travelers to developing countries | Hepatitis A vaccine (HR2) hepatitis B vaccine (HR8)
Blood product recipients | HIV screen (HR3) hepatitis B vaccine (HR8)
High-risk sexual behavior | Hepatitis A vaccine (HR2) HIV screen (HR3) hepatitis B vaccine (HR8) RPR/VDRL (HR9)
Injection or street drug use | PPD (HR1) hepatitis A vaccine (HR2) HIV screen (HR3) hepatitis B vaccine (HR8) RPR/VDRL (HR9) advice to reduce infection risk (HR10)
Health care/lab workers | PPD (HR1) hepatitis A vaccine (HR2) amantadine/rimantadine (HR4) hepatitis B vaccine (HR8)
Persons susceptible to varicella | Varicella vaccine (HR11)

[1] Annually. [2] Mammogram q1-2 yr, or mammogram q1-2 yr with annual clinical breast exam. [3] All women who are or have been sexually active and who have a cervix: q<=3 yr. Consider discontinuation of testing after age 65 yr if previous regular screening with consistently normal results. [*] The ability of clinician counseling to influence this behavior is unproven.

- HR1 =
- HIV positive, close contacts of persons with known or suspected TB, health care workers, persons with medical risk factors associated with TB, immigrants from countries with high TB prevalence, medically underserved low-income populations (including homeless) or living in a shelter, alcoholics, injection drug users, and residents of long-term care facilities (see Ch. 25). See Ch. 25 for indications for BCG vaccine.
- HR2 =
- Persons living in, traveling to, or working in areas where the disease is endemic and where periodic outbreaks occur (e.g., countries with high or intermediate endemicity certain Alaska Native, Pacific Island, Native American, and religious communities) men who have sex with men injection or street drug users. Consider for institutionalized persons and workers in these institutions, and hospital and laboratory workers. Clinicians should also consider local epidemiology (see Ch. 66,67).
- HR3 =
- Men who had sex with men after 1975 past or present injection drug use persons who exchange sex for money or drugs, and their sex partners injection drug-using, bisexual, or HIV-positive sex partner currently or in the past blood transfusion during 1978-1985 persons seeking treatment for STDs. Clinicians should consider local epidemiology (see Ch. 28).
- HR4 =
- Consider for persons who have not received the vaccine or are vaccinated late when the vaccine may be ineffective due to major antigenic changes in the virus for unvaccinated persons who provide home care for high-risk persons to supplement protection provided by vaccine in persons who are expected to have a poor antibody response and for high-risk persons in whom the vaccine is contraindicated (see Ch. 66).
- HR5 =
- Persons aged 75 years and older or aged 70-74 with one or more additional risk factors including: use of certain psychoactive and cardiac medications (e.g., benzodiazepines, antihypertensives) use of >=4 prescription medications impaired cognition, strength, balance, or gait. Intensive individualized home-based multifactorial fall prevention intervention is recommended in settings where adequate resources are available to deliver such services (see Ch. 58).
- HR6 =
- Although evidence is insufficient to recommend routine screening in elderly persons, clinicians should consider cholesterol screening on a case-by-case basis for persons ages 65-75 with additional risk factors (e.g., smoking, diabetes, or hypertension) (see Ch. 2).
- HR7 =
- Persons with a family or personal history of skin cancer, a large number of moles, atypical moles, poor tanning ability, or light skin, hair, and eye color (see Ch. 12).
- HR8 =
- Blood products recipients (including hemodialysis patients), persons with frequent occupational exposure to blood or to blood products, men who have sex with men, injection drug users and their sex partners, persons with multiple recent sex partners persons with other STDs (including HIV), travelers to countries with endemic hepatitis B (see Ch. 66).
- HR9 =
- Persons who exchange sex for money or drugs and their sex partners persons with other STDs (including HIV) and sexual contacts of persons with active syphilis. Clinicians should also consider (see Ch. 26).
- HR10 =
- Persons who continue to inject drugs (see Ch. 53).(High Risk Codes,Table 4.Age 65 and older, continued)
- HR11 =
- Healthy adults without a history of chickenpox or previous immunization. Consider serologic testing may be considered for presumed susceptible adults (see Ch. 65,66).

Table 5. Pregnant Women [**]

Table 5. Pregnant Women [**]

Interventions Considered and Recommended for the Periodic Health Examination
Interventions for the General Population
SCREENING
First visit | Offer multiple marker testing [1] (15-18 wk) [Ch 41]
Blood pressure [Ch 3,37] | Offer serum alpha-fetoprotein [1] (16-18 wk) [Ch 42]
Hemoglobin/hematocrit [Ch 22] | COUNSELING
Hepatitis B surface antigen (HBsAg) [Ch 24] | Tobacco cessation effects of passive smoking [Ch 54]
RPR/VDRL [Ch 26] | Alcohol/other drug use [Ch 52,53]
Chlamydia screen (<25 yr) [Ch 29] | Nutrition, including adequate calcium intake [Ch 56]
Rubella serology or vaccination history [Ch 32] | Encourage breastfeeding [Ch 22,56]
D(Rh) typing, antibody screen [Ch 38] | Lap/shoulder belts [Ch 57]
Offer CVS (<13 wk)[1] or amniocentesis (15-18 wk)[1] (age >=35 yr) [Ch 41] | Infant safety car seats [Ch 57]
Offer hemoglobinopathy screening [Ch 43] | STD prevention: avoid high-risk sexual behavior[*] use condoms[*] [Ch 62]
Assess for problem or risk drinking [Ch 52] | CHEMOPROPHYLAXIS
Offer HIV screening [2][Ch 28] | Multivitamin with folic acid [3] [Ch 42]
Follow-up visits
Blood pressure [Ch 3,37]
Urine culture (12-16 wk) [Ch 31]
Offer amniocentesis (15-18 wk)[1] (age >=35 yr) [Ch 41]
Interventions for High-Risk Populations
POPULATION | POTENTIAL INTERVENTIONS (See detailed high-risk definitions)
High-risk sexual behavior | Screen for chlamydia (1st visit) (HR1), gonorrhea (1st visit) (HR2), HIV (1st visit) (HR3) HBsAg (3rd trimester) (HR4) RPR/VDRL (3rd trimester) (HR5)
Blood transfusion 1978-1985 | HIV screen (1st visit) (HR3)
Injection drug use | HIV screen (HR3) HBsAg (3rd trimester) (HR4) advice to reduce infection risk (HR6)
Unsensitized D-negative women | D(Rh) antibody testing (24-28 wk) (HR7)
Risk factors for Down syndrome | Offer CVS [1] (1st trimester), amniocentesis [1] (15-18 wk) (HR8)
Prior pregnancy with neural tube defect | Folic acid 4.0 mg,[3] offer amniocentesis [1] (15-18 wk) (HR9)

[1] Women with access to counseling and follow-up services, reliable standardized laboratories, skilled high-resolution ultrasound, and, for those receiving serum marker testing, amniocentesis capabilities. [2] Universal screening is recommended for areas (states, counties, or cities) with an increased prevalence of HIV infection among pregnant women. In low-prevalence areas, the choice between universal and targeted screening may depend on other considerations (see Ch. 28). [3] Beginning at least 1 mo before conception and continuing through the first trimester. [*] The ability of clinician counseling to influence this behavior is unproven. [**] See Tables 2 and 3 for other preventive services recommended for women of childbearing age.

- HR1 =
- Women with history of STD or new or multiple sex partners. Clinicians should also consider local epidemiology. Chlamydia screen should be repeated in 3rd trimester if at continued risk (see Ch. 29).
- HR2 =
- Women under age 25 with two or more sex partners in the last year, or whose sex partner has multiple sexual contacts women who exchange sex for money or drugs and women with a history of repeated episodes of gonorrhea. Clinicians should also consider local epidemiology. Gonorrhea screen should be repeated in the 3rd trimester if at continued risk (see Ch. 27).
- HR3 =
- In areas where universal screening is not performed due to low prevalence of HIV infection, pregnant women with the following individual risk factors should be screened: past or present injection drug use women who exchange sex for money or drugs injection drug-using, bisexual, or HIV-positive sex partner currently or in the past blood transfusion during 1978-1985 persons seeking treatment for STDs (see Ch. 28).
- HR4 =
- Women who are initially HBsAg-negative who are at high risk due to injection drug use, suspected exposure to hepatitis B during pregnancy, multiple sex partners (see Ch. 24).
- HR5 =
- Women who exchange sex for money or drugs, women with other STDs (including HIV), and sexual contacts of persons with active syphilis. Clinicians should also consider local epidemiology (see Ch. 26).
- HR6 =
- Women who continue to inject drugs (see Ch. 53).
- HR7 =
- Unsensitized D-negative women (see Ch. 38).
- HR8 =
- Prior pregnancy affected by Down syndrome, advanced maternal age (>=35 yr), known carriage of chromosome rearrangement (see Ch. 41).
- HR9 =
- Women with previous pregnancy affected by neural tube defect (see Ch. 42).

Table 6. Conditions for Which Clinicians Should Remain Alert

## REFERENCES, iii The Periodic Health Examination

Johnson CF. Inflicted injury versus accidental injury. Pediatr Clin North Am. 1990;37:791-814. [pmid: 2199916].
National Highway Traffic Safety Administration. Traffic safety facts 1993: occupant protection. Washington DC: Department of Transportation. 1993.
Campbell BJ. Safety belt injury reduction related to crash severity and front seated position. J Trauma. 1987;27:733-739. [pmid: 3612845].
Cooper PJ. Estimating over involvement of seat belt nonwearers in crashes and the effect of lap/shoulder restraint use on different crash severity consequences. Accid Anal Prev. 1994;26:263-275. [pmid: 8198695].
National Highway Traffic Safety Administration. Final regulatory impact assessment on amendments to Federal Motor Vehicle Safety Standard 208, Front Seat Occupant Protection. Washington, DC: Department of Transportation. 1984;(Publication no. DOT HS 806 572.).
National Highway Traffic Safety Administration. Traffic safety facts 1993. Washington DC: Department of Transportation. 1994.;(Publication no. DOT HS 808 169.).
National Center for Health Statistics. Annual summary of births, marriages, divorces and deaths: United States, 1993. Monthly vital statistics report;vol 42 no 13 (suppl). Hyattsville, MD. Hyattsville, MD. 1994. [pmcid: 330086].
Centers for Disease Control and Prevention. Summary of notifiable diseases, United States, 1993. MMWR. 1994;42:1-73.
Zimmerman HL, Potterat JJ, Dukes RL, et al. Epidemiologic differences between chlamydia and gonorrhea. Am J Public Health. 1990;80:1338-1342. [pmid: 2240301].
Ventura SJ, Taffel SM, Mosher WD, et al. Trends in pregnancies and pregnancy rates, United States, 1980-88. Monthly vital statistics report; vol 41 no 6 (suppl). Hyattsville, MD. Hyattsville, MD. 1992.
Benson V, Marano MA Current estimates from the National Health Interview Survey, 1992. Vital and health statistics; series 10 no 189 Hyattsville, MD Hyattsville, MD 1994View this and related citations using 330086
Schappert SM National Ambulatory Medical Care Survey: 1992 summary. Advance data from vital and health statistics; no 253 Hyattsville, MD Hyattsville, MD 1994View this and related citations using 330086
McCaig LF. Outpatient department summary: National Hospital Ambulatory Medical Care Survey, 1992. Advance data from vital and health statistics; no 248. Hyattsville, MD. Hyattsville, MD. 1994. [pmcid: 330086].
McCaig LF. National Hospital Ambulatory Medical Care Survey: 1992 emergency department summary. Advance data from vital and health statistics; no 245. Hyattsville, MD. Hyattsville, MD. 1994. [pmcid: 330086].
Brody DJ, Pirkle JL, Kramer RA. Blood lead levels in the US population. JAMA. 1994;272:277-283. [pmid: 8028140].
Curran JW, Jaffe HW, Hardy AM, et al. Epidemiology of HIV infection and AIDS in the United States. Science. 1988;239:610-616. [pmid: 3340847].
Department of Health and Human Services, Public Health Service, Office of Disease Prevention and Health Promotion. Clinician's handbook of preventive services. Washington, DC: Government Printing Office. 1994.
Woolf SH, Jonas S, Lawrence RS, eds. Health promotion and disease prevention in clinical practice. Baltimore: Williams & Wilkins. 1995.
American Academy of Pediatrics. Guidelines for health supervision II. Elk Grove Village, IL. Elk Grove Village, IL. 1988. [pmcid: 442803].
American Academy of Pediatrics, Committee on Practice and Ambulatory Medicine. Recommendations for preventive pediatric health care. Pediatrics. 1995;96:373-374. [pmid: 7630705].
Green M, ed. Bright Futures: guidelines for health supervision of infants, children and adolescents. Arlington, VA. Arlington, VA. 1994. [pmcid: 330086].