# Introduction

i Overview

ii Methodology

iii The Periodic Health Examination: Age-Specific Charts

iv Patient Education and Counseling for Prevention

v Cost-Effectiveness and Clinical Preventive Services