# Acknowledgments

The Guide to Clinical Preventive Services, 2nd edition, was prepared under the supervision of the U.S. Preventive Services Task Force, which is solely responsible for its recommendations and whose members are listed on the preceding page. Staff of the Task Force were based at and provided support by the Office of Disease Prevention and Health Promotion, U.S. Department of Health and Human Services. Support from the American College of Preventive Medicine and the Association of Teachers of Preventive Medicine for Task Force activities and staff is gratefully acknowledged. Appreciation is expressed to the members of the Canadian Task Force on the Periodic Health Examination (Richard Goldbloom, M.D., Chair), to their staff (Jennifer Dingle, M.B.A. and Patricia Randel, M.Sc.) and to Wm. Phillip Mickelson, M.D., M.A., liaison from Health Canada to the Canadian Task Force, for their collaboration, manuscript reviews, and support.

In addition to the numerous reviewers identified in Appendix B, appreciation is also expressed to the following individuals:

Specialty Society Liaisons to the U.S. Preventive Services Task Force
- Edgar O. Ledbetter, M.D.
- American Academy of Pediatrics
- Elk Grove Village, IL
- Shirley A. Shelton
- American College of Obstetricians and Gynecologists
- Washington, DC
- Linda Johnson White
- American College of Physicians
- Philadelphia, PA
- Herbert F. Young, M.D.
- American Academy of Family Physicians
- Kansas City, MO

Agency for Health Care Policyand Research Rockville, MD
- Christine Crofton, Ph.D.
- Barbara Fleming, M.D., Ph.D.
- Stephen H. King, M.D.
- David Lanier, M.D.

Centers for Disease Control and Prevention Atlanta, GA
- Alan Hinman, M.D., M.P.H.
- Dixie E. Snyder, M.D., M.P.H.
- William R. Taylor, M.D.
- Steven Teutsch, M.D., M.P.H.

Food and Drug Administration Rockville, MD
- Freddie Ann Hoffman, M.D.
- Peter H. Rheinstein, M.D., J.D., M.S.

Health Resources and Services Administration Rockville, MD
- Colleen Kivlahan, M.D., M.S.P.H.
- William A. Robinson, M.D., M.P.H.
- David B. Snyder, R.Ph., D.D.S.

Indian Health Service Rockville, MD
- Craig Vanderwagen, M.D.

National Institutes of Health Bethesda, MD
- William R. Harlan, M.D.
- John T. Kalberer, Jr., Ph.D.

Substance Abuse and Mental Health Services Administration Rockville, MD
- Mary A. Jansen, Ph.D.
- Elaine M. Johnson, Ph.D.
- Frank J. Sullivan, Ph.D.

Senior Advisors, U.S. Preventive Services Task Force
- E. Harvey Estes, Jr., M.D.
- North Carolina Medical Society Foundation, Inc.
- Raleigh, NC
- Jonathan E. Fielding, M.D., M.P.H.
- UCLA Schools of Public Health and Medicine
- Santa Monica, CA
- Harvey V. Fineberg, M.D., Ph.D.
- Harvard School of Public Health
- Boston, MA
- Gary D. Friedman, M.D., M.S.
- Division of Research, Kaiser Permanente Medical Care Program
- Oakland, CA
- Lawrence W. Green, Dr.P.H.
- University of British Columbia
- Vancouver, British Columbia
- John C. Greene, D.M.D., M.P.H. (ret.)
- University of California at San Francisco School of Dentistry
- San Rafael, CA
- George A. Gross, D.O., M.P.H. (ret.)
- Michigan State University
- East Lansing, MI
- M. Alfred Haynes, M.D.
- Rancho Palos Verdes, CA
- Thomas E. Kottke, M.D.
- Mayo Clinic
- Rochester, MN
- F. Marc LaForce, M.D.
- University of Rochester
- Rochester, NY
- Jack H. Medalie, M.D., M.P.H.
- Case Western Reserve University and Mt. Sinai Medical Center
- Cleveland, OH
- F. Douglas Scutchfield, M.D.
- San Diego State University
- San Diego, CA
- Paul D. Stolley, M.D., M.P.H.
- University of Maryland
- Baltimore, MD
- William H. Wiese, M.D., M.P.H.
- University of New Mexico
- Albuquerque, NM
- Carolyn A. Williams, Ph.D., R.N., F.A.A.N.
- University of Kentucky
- Lexington, KY

Contributing Authors
- Geoffrey Anderson, M.D., Ph.D.
- Sunnybrook Health Science Centre
- North York, Ontario
- Kathlyne Anderson, M.D., M.O.H.
- Harvard School of Public Health
- Boston, MA
- John S. Andrews, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Robert Baldwin, M.D.
- University of Maryland at Baltimore
- Baltimore, MD
- Renaldo N. Battista, M.D., Sc.D., F.R.C.P.C.
- McGill University
- Montreal, Quebec
- Brenda L. Beagan, M.A.
- Dalhousie University
- Halifax, Nova Scotia
- Marie-Dominique Beaulieu, M.D., M.Sc., F.C.F.P.
- University of Montreal
- Montreal, Quebec
- Michelle Berlin, M.D., M.P.H.
- University of Pennsylvania
- Philadelphia, PA
- Dennis Black, Ph.D.
- University of California at San Francisco
- San Francisco, CA
- Joseph N. Blustein, M.D., M.S.
- University of Wisconsin at Madison
- Madison, WI
- John W. Burress, M.D., M.P.H.
- Harvard School of Public Health
- Boston, MA
- Karen J. Carlson, M.D.
- Massachusetts General Hospital
- Boston, MA
- David Christiani, M.D., M.P.H.
- Harvard School of Public Health
- Boston, MA
- Richard Comi, M.D.
- Dartmouth-Hitchcock Medical Center
- Hanover, NH
- Deborah L. Craig, M.P.H.
- Health Care Consultant
- Halifax, Nova Scotia
- Steven R. Cummings, M.D.
- University of California at San Francisco
- San Francisco, CA
- H. Oladele Davies, M.D., M.Sc., F.R.C.P.C.
- University of Calgary
- Calgary, Alberta
- Richard A. Deyo, M.D., M.P.H.
- University of Washington
- Seattle, WA
- Paul Dick, M.D.C.M., F.R.C.P.C.
- University of Toronto
- Toronto, Ontario
- Jennifer Dingle, M.B.A.
- Dalhousie University
- Halifax, Nova Scotia
- Dennis L. Disch, M.D.
- Washington University in St. Louis
- St. Louis, MO
- James Douketis, M.D.
- McMaster University
- Hamilton, Ontario
- Katherine Economy, M.D.
- University of California at San Francisco
- San Francisco, CA
- Wayne Elford, M.D., C.C.F.P., F.C.F.P.
- University of Calgary
- Calgary, Alberta
- Virginia L. Ernster, Ph.D.
- University of California at San Francisco
- San Francisco, CA
- Bruce Ettinger, M.D.
- University of California at San Francisco
- San Francisco, CA
- John W. Feightner, M.D., M.Sc., F.C.F.P.
- McMaster University
- Hamilton, Ontario
- William Feldman, M.D., F.R.C.P.C.
- Hospital for Sick Children
- Toronto, Ontario
- Cary S. Fox, M.S.
- University of California at San Francisco
- San Francisco, CA
- Richard Goldbloom, O.C., M.D., F.R.C.P.C.
- Dalhousie University
- Halifax, Nova Scotia
- Deborah Grady, M.D., M.P.H.
- University of California at San Francisco
- San Francisco, CA
- Cameron Grant, M.B.Ch.B., F.R.A.C.P.
- University of Auckland
- Auckland, New Zealand
- Jean L. Haggerty, M.Sc.
- McGill University
- Montreal, Quebecael
- Amid I. Ismail, B.D.S., M.P.H., Dr.P.H.
- Dalhousie University
- Halifax, Nova Scotia
- James G. Kahn, M.D., M.P.H.
- University of California at San Francisco
- San Francisco, CA
- Amnon Lahad, M.D., M.P.H.
- University of Washington
- Seattle, WA
- John F. Laurenzo, M.D.
- University of Iowa
- Iowa City, IA
- Donald W. Lewis, D.D.S., D.D.P.H., M.Sc.D., F.R.C.D.C.
- University of Toronto
- Toronto, Ontario
- Alexander G. Logan, M.D., F.R.C.P.C.
- Mount Sinai Hospital
- Toronto, Ontario
- Sarvesh Logsetty, M.D.
- Hospital for Sick Children
- Toronto, Ontario
- Kate Lorig, R.N., Dr.P.H.
- Stanford University
- Palo Alto, CA
- Harriet L. MacMillan, M.D., F.R.C.P.C.
- McMaster University
- Hamilton, Ontario
- James H. MacMillan, M.Sc.
- Glaxo Canada, Inc.
- Mississauga, Ontario
- Alex Malter, M.D., M.P.H.
- University of Washington
- Seattle, WA
- Anne Martell, M.A., C.M.C.
- Martell Consulting Services, Ltd.
- Halifax, Nova Scotia
- Susan E. Moner, M.D.
- University of Toronto
- Toronto, Ontario
- Brenda J. Morrison, Ph.D.
- University of British Columbia
- Vancouver, British Columbia
- Lindsay E. Nicolle, M.D.
- University of Manitoba
- Winnipeg, Manitoba
- David R. (Dan) Offord, M.D.
- Chedoke-McMaster Hospitals
- Hamilton, Ontario
- Christopher Patterson, M.D., F.R.C.P.C.
- Chedoke-McMaster Hospitals
- Hamilton, Ontario
- Diana B. Petitti, M.D., M.P.H.
- Kaiser Permanente
- Los Angeles, CA
- M. Carrington Reid, M.D., Ph.D.
- Yale University
- New Haven, CT
- Carl Rosati, M.D., F.r.C.S.C.
- North York Branson Hospital
- North York, Ontario
- Susan M. Rubin, M.P.H.
- University of California at San Francisco
- San Francisco, CA
- Daniel E. Singer, M.D.
- Massachusetts General Hospital
- Boston, MA
- Steven J. Skates, Ph.D.
- Massachusetts General Hospital
- Boston, MA
- Michael B.H. Smith, M.B., B.Ch., C.C.F.P., F.R.C.P.C.
- Dalhousie University
- Halifax, Nova Scotia
- Walter O. Spitzer, M.D., M.P.H.
- McGill University
- Montreal, Quebec
- Stephen R. Tabet, M.D., M.P.H.
- University of Washington
- Seattle, Washington
- Denise Tonner, M.D.
- University of Iowa
- Iowa City, IA
- Elaine Wang, M.D., C.M., M.Sc., F.R.C.P.C.
- Hospital for Sick Children
- Toronto, Ontario

Other Contributors to the U.S. Preventive Services Task Force
- Hanan S. Bell, Ph.D.
- American Academy of Family Physicians
- Kansas City, MO
- David M. Eddy, M.D., Ph.D.
- Kaiser Permanente Medical Care Program
- Pasadena, CA
- John M. Eisenberg, M.D., M.B.A.
- Georgetown University
- Washington, DC
- Charles M. Goldstein
- National Library of Medicine
- Bethesda, MD
- Sheldon Greenfield, M.D.
- New England Medical Center
- Boston, MA
- Robert S.A. Hayward, M.D., M.P.H.
- McMaster University
- Hamilton, Ontario
- David L. Sackett, M.D., M.Sc.
- University of Oxford
- Oxford, England
- Stephen Thacker, M.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

Office of Disease Prevention and Health Promotion
- James Harrell, M.A., Deputy Director
- John C. Bailar III, M.D., Ph.D.
- Rachel Ballard-Barbash, M.D., M.P.H.
- David Baker
- Karil Bialostosky, M.S.
- Darla Danford, M.P.H., D.Sc.
- Larry L. Dickey, M.D., M.P.H.
- Martha Frazier
- Walter Glinsmann, M.D.
- Marthe Gold, M.D., M.P.H.
- Patricia Lacey
- Linda Meyers, Ph.D.
- Janice T. Radak
- Marilyn Schulenberg
- Joanna E. Siegel, Sc.D.
- Marilyn G. Stephenson, M.S., R.D.
- Carla Y. Williams
- Jonathan Winickoff, Summer Intern

Preventive Medicine Residents
- Barbara Albert, M.D., M.S.
- University of Maryland
- Baltimore, MD
- C. Marlo Baird, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Arthur R. Baker, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Robert Beardall, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Daniel Bleed, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Paul Denning, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- S. Patrick Kachur, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Marisa Moore, M.D., M.P.H.
- Mayo Clinic
- Rochester, MN
- Ann S. O'Malley, M.D., M.P.H.
- University of Maryland
- Baltimore, MD
- Peter W. Pendergrass, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Robert Reid, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Donald B. Robinson, M.D., M.P.H.
- The Johns Hopkins University
- Baltimore, MD
- Lynda Sisson, M.D., M.P.H.
- Mayo Clinic
- Rochester, MN
- Natalie J. Smith, M.D., M.P.H.
- University of California at Berkeley
- Berkeley, CA
- Mark S. Smolinski, M.D., M.P.H.
- University of Arizona
- Tucson, AZ
- Craig F. Thompson, M.D., M.S.P.H.
- University of Kentucky
- Lexington, KY
- Mary Jo Trepka, M.D., M.S.P.H.
- University of Colorado
- Denver, CO

American College of Preventive Medicine(Logistical and administrative support)
- Hazel K. Keimowitz, M.A.
- Executive Director
- Rebecca Kingsley
- Emily P. Slough

RII (Logistical support)
- Janet E. Meleney, M.A.
- Project Manager
- Ola Bamgbase
- Kirsten Moore