# Task Force Staff

- Carolyn DiGuiseppi, M.D., M.P.H
- Editor, Science Writer, and Project Director

- David Atkins, M.D., M.P.H.
- Editor and Science Writer

- Steven H. Woolf, M.D., M.P.H.
- Editor and Science Writer

- Douglas B. Kamerow, M.D., M.P.H.
- Managing Editor

- Abigail L. Rose
- Project Associate