# U.S. Preventive Services Task Force

- Harold C. Sox, Jr., M.D., Chair
- Joseph M. Huber Professor and Chair Department of Medicine
- Dartmouth-Hitchcock Medical Center
- Lebanon, NH

- Donald M. Berwick, M.D., M.P.P., Vice Chair
- Associate Clinical Professor
- Department of Pediatrics
- Harvard Medical School
- Boston, MA

- Alfred O. Berg, M.D., M.P.H.
- Professor and Associate Chair
- Department of Family Medicine
- University of Washington
- Seattle, WA

- Paul S. Frame, M.D.
- Tri-County Family Medicine
- Cohocton, NY
- Clinical Associate Professor
- Department of Family Medicine
- University of Rochester School of Medicine and Dentistry
- Rochester, NY

- Dennis G. Fryback, Ph.D.
- Professor of Preventive Medicine and Industrial Engineering
- Department of Preventive Medicine
- University of Wisconsin-Madison
- Madison, WI

- David A. Grimes, M.D.
- Professor and Vice Chair
- Department of Obstetrics, Gynecology and Reproductive Sciences
- UCSF/San Francisco General Hospital
- San Francisco, CA

- Robert S. Lawrence, M.D.
- Associate Dean for Professional Education and Programs
- Professor of Health Policy and Management
- The Johns Hopkins School of Hygiene and Public Health
- Baltimore, MD

- Robert B. Wallace, M.D., M.Sc.
- Professor of Preventive Medicine
- Director, University of Iowa Cancer Center
- University of Iowa College of Medicine
- Iowa City, IA

- A. Eugene Washington, M.D., M.Sc.
- Professor and Chief
- Department of Obstetrics, Gynecology, and Reproductive Sciences
- UCSF/Mount Zion Medical Center
- Director, Medical Effectiveness Research Center for Diverse Populations/UCSF
- San Francisco, CA

- Modena E.H. Wilson, M.D., M.P.H.
- Professor of Pediatrics
- Director, Division of General Pediatrics
- The Johns Hopkins Children's Center
- Baltimore, MD