# Topics in Progress

Each USPSTF recommendation goes through several stages of development. The review process takes into account input from the medical and research community, stakeholders, and the general public.

The length of time for the entire recommendation process varies depending on the amount and type of available evidence and the time required for compilation of data into a draft recommendation, public comment periods, consideration of comments, and in-depth review and discussions among USPSTF members.

The following topics are in review and are likely to be issued as drafts for public comment during 2014:

■ Aspirin for the Prevention of Cardiovascular Disease
■ Aspirin or NSAIDS for the Prevention of Colorectal Cancer, Preventive Medications
■ Aspirin Use to Prevent Preeclampsia, Preventive Medications
■ Chlamydial Infection, Screening
■ Diabetes Mellitus, Screening
■ Gonorrhea, Screening
■ Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults at Risk, Counseling
■ High Blood Pressure in Adults, Screening
■ Iron Deficiency Anemia in Childhood and Pregnancy, Screening
■ Major Depressive Disorder in Children and Adolescents, Screening
■ Sexually Transmitted Infections, Counseling
■ Thyroid Disease, Screening
■ Vitamin D Deficiency, Screening

Recommendations on the following topics were published during the production of the 2014 Guide to Clinical Preventive Services or are in review and are likely to be published as final recommendations during 2014:

■ Abdominal Aortic Aneurysm, Screening
■ Carotid Artery Stenosis, Screening
■ Dental Caries Prevention in Children From Birth to Age 5 Years, Screening and Preventive Medications
■ Hepatitis B Virus Infection in Nonpregnant Adolescents and Adults, Screening
■ Suicide Risk, Screening

The following topics are in earlier stages of review and are likely to be issued as drafts or published as final recommendations sometime after 2014:

■ Autism Spectrum Disorder in Young Children, Screening
■ Breast Cancer, Screening
■ Chronic Obstructive Pulmonary Disease, Screening
■ Colorectal Cancer, Screening
■ Depression in Adults and in Pregnant and Postpartum Women, Screening
■ Impaired Visual Acuity in Older Adults, Screening
■ Lipid Disorders in Adults, Screening
■ Lipid Disorders in Children, Screening
■ Skin Cancer, Screening
■ Speech and Language Delay and Disorders in Children Age 5 Years or Younger, Screening
■ Syphilis Infection, Screening
■ Tobacco Cessation in Adults, Including Pregnant Women, Counseling