# More Resources

## AHRQ's Improving Primary Care Program

AHRQ's Improving Primary Care Program Web site (www.ahrq.gov/improvingprimarycare) produces evidence and tools to transform the primary care delivery system, resulting in better care, better experiences, and better value. The Program's Web site includes tools, resources, and materials to support health care organizations and engage the entire health care delivery system.

The Program includes two overall project areas with specific areas of focus:

■ Improving Primary Care Practice
  – Capacity building
  – Care coordination
  – Clinical-community linkages
  – Health care/system redesign
  – Health information technology integration
  – Behavioral and mental health
  – Primary care practice-based research networks
  – Self-management support
■ Evidence-Based Decisionmaking
  – Clinical decision support
  – Multiple chronic conditions
  – Research centers for excellence in clinical preventive services
  – U.S. Preventive Services Task Force

## myhealthfinder

A consumer-friendly resource, myhealthfinder (available at www.healthfinder.gov) helps people create a customized list of relevant recommendations for preventive services based on age, sex, and pregnancy status, along with explanations of each recommendation in plain language.

## Stay Healthy Brochures

Consumers can use the information in this series of brochures to learn which screening tests you need and when to get them, which medicines may prevent diseases, and daily steps to take for good health. The series includes Men Stay Healthy at Any Age, Women Stay Healthy at Any Age, Men Stay Healthy at 50+, and Women Stay Healthy at 50+, all in English and Spanish. Go to http://www.ahrq.gov/patients-consumers/prevention/lifestyle/index.html for the list and choose the title you are interested in.

## Community Preventive Services Task Force

Established in 1996 by the U.S. Department of Health and Human Services, the Community Preventive Services Task Force (CPSTF) complements the work of the USPSTF, by addressing preventive services at the community level. The CPSTF assists agencies, organizations, and individuals at all levels (national, State, community, school, worksite, and health care system) by providing evidence-based recommendations about community prevention programs and policies that are effective in saving lives, increasing longevity, and improving Americans' quality of life. The recommendations of the CPSTF are available at www.thecommunityguide.org.

## Advisory Committee on Immunization Practices

The Advisory Committee on Immunization Practices, managed and supported by the Centers for Disease Control and Prevention, is a group of medical and public health experts that develops recommendations on how to use vaccines to control diseases in the United States. The recommendations stand as public health advice that will lead to a reduction in the incidence of vaccine preventable diseases and an increase in the safe use of vaccines and related biological products.

## The Substance Abuse and Mental Health Services Administration

The Substance Abuse and Mental Health Services Administration provides resources that help health care providers locate and utilize behavioral health services. The Treatment Locator (findtreatment.samhsa.gov) helps find alcohol and drug abuse treatment or mental health treatment facilities and programs around the country, and the National SBIRT Addiction Technology Transfer Center (ireta.org/ebpsbirt) helps utilize the public health model of screening and counseling to patients on risky or harmful drug and alcohol use.

## Healthy People 2020

Healthy People 2020 is an initiative from the U.S. Department of Health and Human Services that challenges individuals, communities, and professionals to take specific steps to ensure good health. Healthy People provides science-based, 10-year national objectives for improving the health of all Americans. Read more at www.healthypeople.gov/2020/default.aspx.

## National Guideline Clearinghouse™

A public resource for evidence-based clinical practice guidelines, NGC (guideline.gov/index.aspx) was originally created by AHRQ in partnerships with the American Medical Association and the American Association of Health Plans (now America's Health Insurance Plans). The NGC mission is to provide physicians and other health professionals, health care providers, health plans, integrated delivery systems, purchasers, and others an accessible mechanism for obtaining objective, detailed information on clinical practice guidelines and to further their dissemination, implementation, and use of this information.

## Canadian Task Force on Preventive Health Care

The Task Force was established by the Public Health Agency of Canada to develop clinical practice guidelines that support primary care providers in delivering preventive health care. The mandate of the Task Force is to develop and disseminate clinical practice guidelines for primary and preventive care, based on systematic analysis of scientific evidence. Read more at www.canadiantaskforce.ca/.

## Cancer Control P.L.A.N.E.T

A service of the National Cancer Institute, the Cancer Control P.L.A.N.E.T. portal provides access to Web-based resources that can help planners, program staff, and researchers to design, implement, and evaluate evidence-based cancer control programs. Read more at cancercontrolplanet.cancer.gov/index.html.

## HealthCare.gov

This Web site (www.healthcare.gov), managed by the U.S. Department of Health and Human Services, helps people take health care into their own hands. It provides information about insurance options, using insurance, the Affordable Care Act, comparing providers, and prevention and wellness—including which preventive services are covered under the Act.