# Members of the U.S. Preventive Services Task Force 2004-2014

- Janet D. Allan, Ph.D., R.N., C.S., F.A.A.N.
  School of Nursing
  University of Maryland, Baltimore
  Baltimore, MD
- Linda Ciofu Baumann, Ph.D., R.N.
  School of Nursing and School of Medicine & Public Health
  University of Wisconsin
  Madison, WI
- Alfred O. Berg, M.D., M.P.H.
  University of Washington
  Seattle, WA
- Kirsten Bibbins-Domingo, Ph.D., M.D.
  San Francisco General Hospital
  University of California,
  San Francisco, CA
- Adelita Gonzales Cantu, R.N., Ph.D.
  University of Texas Health Science Center
  San Antonio, TX
- Ned Calonge, M.D., M.P.H.
  Colorado Department of Public Health and Environment
  Denver, CO
- Susan J. Curry, Ph.D.
  College of Public Health
  University of Iowa
  Iowa City, IA
- Karina W. Davidson, Ph.D., M.A.Sc.
  Center for Behavioral Cardiovascular Health
  Columbia University Medical Center
  New York, NY
- Tomas G. DeWitt, M.D.
  Department of Pediatrics
  Children's Hospital Medical Center
  Cincinnati, OH
- Allen J. Dietrich, M.D.
  Dartmouth Medical School
  Hanover, NH
- Mark Ebell, M.D., M.S.
  The University of Georgia
  Athens, GA
- Glenn Flores, M.D.
  University of Texas
  Southwestern Medical Center and Children's Medical Center of Dallas
  Dallas, TX
- Paul S. Frame, M.D.
  Tri-County Family Medicine
  Cohocton, NY
- Francisco A.R. García, M.D., M.P.H.
  Pima County Department of Health
  Tucson, AZ
- Matthew W. Gillman, M.D., S.M.
  Obesity Prevention Program
  Harvard Medical School and Harvard Pilgrim Health Care Institute
  Boston, MA
- Leon Gordis, M.D., Dr.P.H.
  Johns Hopkins Bloomberg School of Public Health
  Baltimore, MD
- Kimberly D. Gregory, M.D., M.P.H.
  Cedars-Sinai Medical Center
  Los Angeles, CA
- David Grossman, M.D., M.P.H.
  Center for Health Studies, Group Health Cooperative
  University of Washington
  Seattle, WA
- Russell Harris, M.D., M.P.H.
  University of North Carolina School of Medicine
  Chapel Hill, NC
- Jessica Herzstein, M.D., M.P.H.
  Air Products
  Allentown, PA
- George Isham, M.D., M.S.
  HealthPartners
  Minneapolis, MN
- Mark S. Johnson, M.D., M.P.H.
  New Jersey Medical School
  University of Medicine and Dentistry of New Jersey
  Newark, NJ
- Alex R. Kemper, M.D., M.P.H., M.S.
  Pediatrics
  Duke University Medical School
  Durham, NC
  Division of Children's Primary Care
  Duke University
  Durham, NC
- Kenneth Kizer, M.D., M.P.H.
  National Quality Forum
  Washington, DC
- Jonathan D. Klein, M.D., M.P.H.
  University of Rochester
  Rochester, NY
- Ann E. Kurth, Ph.D., R.N., M.S.N., M.P.H.
  College of Nursing and the Department of Population Health
  Global Institute of Public Health
  New York University
  New York, NY
- Michael L. LeFevre, M.D., M.S.P.H.
  University of Missouri School of Medicine
  Columbia, MO
- Rosanne Leipzig, M.D., Ph.D.
  Mount Sinai School of Medicine
  New York, NY
- Carol Loveland-Cherry, Ph.D., R.N., F.A.A.N.
  School of Nursing
  University of Michigan
  Ann Arbor, MI
- Lucy N. Marion, Ph.D., R.N.
  School of Nursing
  Medical College of Georgia
  Augusta, GA
- Joy Melnikow, M.D., M.P.H.
  University of California Davis
  Sacramento, CA
- Bernadette Melnyk, Ph.D., R.N., C.P.N.P./N.P.P.
  College of Nursing & Healthcare Innovation
  Arizona State University
  Phoenix, AZ
- Virginia A. Moyer, M.D., M.P.H.
  University of Texas Health Science Center
  Houston, TX
- Wanda Nicholson, M.D., M.P.H., M.B.A.
  Johns Hopkins School of Medicine and Bloomberg School of Public Health
  Baltimore, MD
- Judith K. Ockene, Ph.D., M.Ed.
  University of Massachusetts Medical School
  Worcester, MA
- Douglas K. Owens, M.D., M.S.
  VA Palo Alto Health Care System
  Freeman Spogli Institute for International Studies
  Stanford University
  Stanford, CA
- Diana B. Petitti, M.D., M.P.H.
  Fulton School of Engineering
  Arizona State University
  Tempe, AZ
- William R. Phillips, M.D., M.P.H.
  Family Medicine and Health Services
  University of Washington
  Seattle, WA
- Maureen G. Phipps, M.D., M.P.H.
  Department of Obstetrics and Gynecology
  Warren Alpert Medical School
  Brown University, Providence, RI
- Michael P. Pignone, M.D., M.P.H.
  Division of General Internal Medicine
  University of North Carolina
  Chapel Hill, NC
- Carolina Reyes, M.D.
  University of Southern California, Los Angeles County/USC Medical Center
  Los Angeles, CA
- George F. Sawaya, M.D.
  University of California, San Francisco
  San Francisco, CA
- J. Sanford (Sandy) Schwartz, M.D.
  University of Pennsylvania School of Medicine and Wharton School
  Philadelphia, PA
- Albert L. Siu, M.D.
  Mount Sinai Medical Center
  New York, NY
- Steven M. Teutsch, M.D., M.P.H.
  Merck and Company, Inc.
  West Point, PA
- Timothy Wilt, M.D., M.P.H.
  Minneapolis VA Medical Center
  University of Minnesota
  Minneapolis, MN
- Barbara P. Yawn, M.D., M.S.P.H., M.Sc.
  Olmstead Medical Center
  Rochester, MN