# Clinical Summaries of Recommendations for Adults

## Abdominal Aortic Aneurysm

Title | Screening for Abdominal Aortic Aneurysm
Population | Men ages 65 to 75 years who have ever smoked | Men ages 65 to 75 years who have never smoked | Women ages 65 to 75 years
Recommendation | Screen once for abdominal aortic aneurysm with ultrasonography. Grade: B | No recommendation for or against screening. Grade: C | Do not screen for abdominal aortic aneurysm. Grade: D

Risk Assessment | The major risk factors for abdominal aortic aneurysm include male sex, a history of ever smoking (defined as 100 cigarettes in a person's lifetime), and age of 65 years or older.
Screening Tests | Screening abdominal ultrasonography is an accurate test when performed in a setting with adequate quality assurance (i.e., in an accredited facility with credentialed technologists). Abdominal palpation has poor accuracy and is not an adequate screening test.
Timing of Screening | One-time screening to detect an abdominal aortic aneurysm using ultrasonography is sufficient. There is negligible health benefit in re-screening those who have normal aortic diameter on initial screening.
Interventions | Open surgical repair of an aneurysm of at least 5.5 cm leads to decreased abdominal aortic aneurysm-related mortality in the long term; however, there are major harms associated with this procedure.
Balance of Benefits and Harms | In men ages 65 to 75 years who have ever smoked, the benefits of screening for abdominal aortic aneurysm outweigh the harms. | In men ages 65 to 75 years who have never smoked, the balance between the benefits and harms of screening for abdominal aortic aneurysm is too close to make a general recommendation for this population. | The potential overall benefit of screening for abdominal aortic aneurysm among women ages 65 to 75 years is low because of the small number of abdominal aortic aneurysm-related deaths in this population and the harms associated with surgical repair.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for carotid artery stenosis, coronary heart disease, high blood pressure, lipid disorders, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## * * New recommendations released March 2012 to March 2014. Alcohol Misuse

Title | Screening and Behavioral Counseling Interventions in Primary Care To Reduce Alcohol Misuse
Population | Adults aged 18 years or older | Adolescents
Recommendation | Screen for alcohol misuse and provide brief behavioral counseling interventions to persons engaged in risky or hazardous drinking. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Screening Tests | Numerous screening instruments can detect alcohol misuse in adults with acceptable sensitivity and specificity. The USPSTF prefers the following tools for alcohol misuse screening in the primary care setting:; 1. AUDIT; 2. Abbreviated AUDIT-C; 3. Single-question screening, such as asking, “How many times in the past year have you had 5 (for men) or 4 (for women and all adults older than 65 years) or more drinks in a day?”
Behavioral Counseling Interventions | Counseling interventions in the primary care setting can improve unhealthy alcohol consumption behaviors in adults engaging in risky or hazardous drinking. Behavioral counseling interventions for alcohol misuse vary in their specific components, administration, length, and number of interactions. Brief multicontact behavioral counseling seems to have the best evidence of effectiveness; very brief behavioral counseling has limited effect.
Balance of Benefits and Harms | There is a moderate net benefit to alcohol misuse screening and brief behavioral counseling interventions in the primary care setting for adults aged 18 years or older. | The evidence on alcohol misuse screening and brief behavioral counseling interventions in the primary care setting for adolescents is insufficient, and the balance of benefits and harms cannot be determined.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for illicit drug use and counseling and interventions to prevent tobacco use. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Aspirin for the Prevention of Cardiovascular Disease

Title | Aspirin for the Prevention of Cardiovascular Disease
Population | Men age 45–79 years | Women age 55–79 years | Men age <45 years | Women age <55 years | Men & Women age ≥80 years
Recommendation | Encourage aspirin use when potential CVD benefit (MIs prevented) outweighs potential harm of GI hemorrhage. | Encourage aspirin use when potential CVD benefit (strokes prevented) outweighs potential harm of GI hemorrhage. | Do not encourage aspirin use for MI prevention. | Do not encourage aspirin use for stroke prevention. | No Recommendation
| Grade: A | | Grade: D | | Grade: I (Insufficient Evidence)

How to Use This Recommendation | Shared decisionmaking is strongly encouraged with individuals whose risk is close to (either above or below) the estimates of 10-year risk levels indicated below. As the potential CVD benefit increases above harms, the recommendation to take aspirin should become stronger. To determine whether the potential benefit of MIs prevented (men) and strokes prevented (women) outweighs the potential harm of increased GI hemorrhage, both 10-year CVD risk and age must be considered. Risk level at which CVD events prevented (benefit) exceeds GI harms
How to Use This Recommendation | Men 10-year CHD risk | | Women 10-year stroke risk
How to Use This Recommendation | Age 45–59 years | ≥4% | Age 55–59 years | ≥3%
How to Use This Recommendation | Age 60–69 years | ≥9% | Age 60–69 years | ≥8%
How to Use This Recommendation | Age 70–79 years | ≥12% | Age 70–79 years | ≥11%
How to Use This Recommendation | The table above applies to adults who are not taking NSAIDs and who do not have upper GI pain or a history of GI ulcers. NSAID use and history of GI ulcers raise the risk of serious GI bleeding considerably and should be considered in determining the balance of benefits and harms. NSAID use combined with aspirin use approximately quadruples the risk of serious GI bleeding compared to the risk with aspirin use alone. The rate of serious bleeding in aspirin users is approximately 2–3 times higher in patients with a history of GI ulcers.
Risk Assessment | For men: Risk factors for CHD include age, diabetes, total cholesterol level, HDL level, blood pressure, and smoking. CHD risk estimation tool: cvdrisk.nhlbi.nih.gov/calculator.asp For women: Risk factors for ischemic stroke include age, high blood pressure, diabetes, smoking, history of CVD, atrial fibrillation, and left ventricular hypertrophy. Stroke risk estimation tool: http://www.westernstroke.org/index.php?header_name=stroke_tools.gif&main=stroke_tools.php
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for abdominal aortic aneurysm, carotid artery stenosis, coronary heart disease, high blood pressure, lipid disorders, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org.

Abbreviations: CHD = coronary heart disease, CVD = cardiovascular disease, GI = gastrointestinal, HDL = high-density lipoprotein, MI = myocardial infarction, NSAIDs = nonsteroidal anti-inflammatory drugs.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Aspirin or NSAIDs for Prevention Of Colorectal Cancer

Title | Routine Aspirin or Nonsteroidal Anti-Inflammatory Drug (NSAID) Use for the Primary Prevention of Colorectal Cancer
Population | Asymptomatic adults at average risk for colorectal cancer
Recommendation | Do not use aspirin or NSAIDs for the prevention of colorectal cancer. Grade: D

Risk Assessment | The major risk factors for colorectal cancer are older age (older than age 50 years), family history (having two or more first-or second-degree relatives with colorectal cancer), and African American race.
Balance of Benefits and Harms | Aspirin and NSAIDs, taken in higher doses for longer periods, reduce the incidence of adenomatous polyps. However, there is poor evidence that aspirin and NSAID use leads to a reduction in colorectal cancer-associated mortality. Aspirin increases the incidence of gastrointestinal bleeding and hemorrhagic stroke; NSAIDs increase the incidence of gastrointestinal bleeding and renal impairment, especially in the elderly. The USPSTF concluded that the harms outweigh the benefits of aspirin and NSAID use for the prevention of colorectal cancer.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for colorectal cancer and aspirin use for the prevention of cardiovascular disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Bacterial Vaginosis in Pregnancy

Title | Screening for Bacterial Vaginosis in Pregnancy to Prevent Preterm Delivery
Population | Asymptomatic pregnant women without risk factors for preterm delivery | Asymptomatic pregnant women with risk factors for preterm delivery
Recommendation | Do not screen. Grade: D | No recommendation. Grade: I (Insuffcient Evidence)

Risk Assessment | Risk factors of preterm delivery include:; - African-American women.; - Pelvic infection.; - Previous preterm delivery.; Bacterial vaginosis is more common among African-American women, women of low socioeconomic status, and women who have previously delivered low-birth-weight infants.
Screening Tests | Bacterial vaginosis is diagnosed using Amsel's clinical criteria or Gram stain. When using Amsel's criteria, 3 out of 4 criteria must be met to make a clinical diagnosis:; 1. Vaginal pH >4.7.; 2. The presence of clue cells on wet mount.; 3. Thin homogeneous discharge.; 4. Amine ‘fishy odor’ when potassium hydroxide is added to the discharge.
Screening Intervals | Not applicable.
Treatment | Treatment is appropriate for pregnant women with symptomatic bacterial vaginosis infection. Oral metronidazole and oral clindamycin, as well as vaginal metronidazole gel or clindamycin cream, are used to treat bacterial vaginosis. The optimal treatment regimen is unclear.^1^

1 The Centers for Disease Control and Prevention (CDC) recommends 250 mg oral metronidazole 3 times a day for 7 days as the treatment for bacterial vaginosis in pregnancy.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Bacteriuria

Title | Screening for Asymptomatic Bacteriuria in Adults
Population | All pregnant women | Men and nonpregnant women
Recommendation | Screen with urine culture. Grade: A | Do not screen. Grade: D

Detection and Screening Tests | Asymptomatic bacteriuria can be reliably detected through urine culture. The presence of at least 10^5^ colony-forming units per mL of urine, of a single uropathogen, and in a midstream clean-catch specimen is considered a positive test result.
Screening Intervals | A clean-catch urine specimen should be collected for screening culture at 12–16 weeks' gestation or at the first prenatal visit, if later. The optimal frequency of subsequent urine testing during pregnancy is uncertain. | Do not screen.
Benefits of Detection and Early Treatment | The detection and treatment of asymptomatic bacteriuria with antibiotics significantly reduces the incidence of symptomatic maternal urinary tract infections and low birthweight. | Screening men and nonpregnant women for asymptomatic bacteriuria is ineffective in improving clinical outcomes.
Harms of Detection and Early Treatment | Potential harms associated with treatment of asymptomatic bacteriuria include:; - Adverse effects from antibiotics.; - Development of bacterial resistance.
Other Relevant USPSTF Recommendations | Additional USPSTF recommendations involving screening for infectious conditions during pregnancy can be found at www.uspreventiveservicestaskforce.org/recommendations.htm#obstetric and www.uspreventiveservicestaskforce.org/recommendations.htm#infectious.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Bladder Cancer

Title | Screening for Bladder Cancer
Population | Asymptomatic adults
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Risk factors for bladder cancer include:; - Smoking; - Occupational exposure to carcinogens (e.g., rubber, chemical, and leather industries); - Male sex; - Older age; - White race; - Infections caused by certain bladder parasites; - Family or personal history of bladder cancer
Screening Tests | Screening tests for bladder cancer include:; - Microscopic urinalysis for hematuria; - Urine cytology; - Urine biomarkers
Interventions | The principal treatment for superficial bladder cancer is transurethral resection of the bladder tumor, which may be combined with adjuvant radiation therapy, chemotherapy, biologic therapies, or photodynamic therapies. Radical cystectomy, often with adjuvant chemotherapy, is used in cases of surgically resectable invasive bladder cancer.
Balance of Benefits and Harms | There is inadequate evidence that treatment of screen-detected bladder cancer leads to improved morbidity or mortality. There is inadequate evidence on harms of screening for bladder cancer.
Suggestions for Practice | In deciding whether to screen for bladder cancer, clinicians should consider the following:; - Potential preventable burden: early detection of tumors with malignant potential could have an important impact on the mortality rate of bladder cancer.; - Potential harms: false-positive results may lead to anxiety and unneeded evaluations, diagnostic-related harms from cystoscopy and biopsy, harms from labeling and unnecessary treatments, and overdiagnosis.; - Current practice: screening tests used in primary practice include microscopic urinalysis for hematuria and urine cytology; urine biomarkers are not commonly used in part because of cost. Patients with positive findings are typically referred to a urologist for further evaluation.
Other Relevant USPSTF Recommendations | Recommendations on screening for other types of cancer can be found at www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *BRCA-Related Cancer in Women

Title | Risk Assessment, Genetic Counseling, and Genetic Testing for BRCA-Related Cancer In Women
Population | Asymptomatic women who have not been diagnosed with BRCA-related cancer
Recommendation | Screen women whose family history may be associated with an increased risk for potentially harmful BRCA mutations. Women with positive screening results should receive genetic counseling and, if indicated after counseling, BRCA testing. Grade: B | Do not routinely recommend genetic counseling or BRCA testing to women whose family history is not associated with an increased risk for potentially harmful BRCA mutations. Grade: D

Risk Assessment | Family history factors associated with increased likelihood of potentially harmful BRCA mutations include breast cancer diagnosis before age 50 years, bilateral breast cancer, family history of breast and ovarian cancer, presence of breast cancer in ≥1 male family member, multiple cases of breast cancer in the family, ≥1 or more family member with 2 primary types of BRCA-related cancer, and Ashkenazi Jewish ethnicity. Several familial risk stratification tools are available to determine the need for in-depth genetic counseling, such as the Ontario Family History Assessment Tool, Manchester Scoring System, Referral Screening Tool, Pedigree Assessment Tool, and FHS-7.
Screening Tests | Genetic risk assessment and BRCA mutation testing are generally multistep processes involving identification of women who may be at increased risk for potentially harmful mutations, followed by genetic counseling by suitably trained health care providers and genetic testing of selected high-risk women when indicated. Tests for BRCA mutations are highly sensitive and specific for known mutations, but interpretation of results is complex and generally requires posttest counseling.
Treatment | Interventions in women who are BRCA mutation carriers include earlier, more frequent, or intensive cancer screening; risk-reducing medications (e.g., tamoxifen or raloxifene); and risk-reducing surgery (e.g., mastectomy or salpingo-oophorectomy).
Balance of Benefits and Harms | In women whose family history is associated with an increased risk for potentially harmful BRCA mutations, the net benefit of genetic testing and early intervention is moderate. | In women whose family history is not associated with an increased risk for potentially harmful BRCA mutations, the net benefit of genetic testing and early intervention ranges from minimal to potentially harmful.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on medications for the reduction of breast cancer risk and screening for ovarian cancer. These recommendations are available at www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to www.uspreventiveservicestaskforce.org.

## *Breast Cancer (Preventive Medications)

Title | Medications for Risk Reduction of Primary Breast Cancer in Women
Population | Asymptomatic women aged ≥35 years without a prior diagnosis of breast cancer who are at increased risk for the disease | Asymptomatic women aged ≥35 years without a prior diagnosis of breast cancer who are not at increased risk for the disease
Recommendation | Engage in shared, informed decision making and offer to prescribe risk-reducing medications, if appropriate. Grade: B | Do not prescribe risk-reducing medications. Grade: D

Risk Assessment | Important risk factors for breast cancer include patient age, race/ethnicity, age at menarche, age at first live childbirth, personal history of ductal or lobular carcinoma in situ, number of first-degree relatives with breast cancer, personal history of breast biopsy, body mass index, menopause status or age, breast density, estrogen and progestin use, smoking, alcohol use, physical activity, and diet. Available risk assessment models can accurately predict the number of breast cancer cases that may arise in certain study populations, but their ability to accurately predict which women will develop breast cancer is modest.
Preventive Medications | The selective estrogen receptor modulators tamoxifen and raloxifene have been shown to reduce the incidence of invasive breast cancer in women who are at increased risk for the disease. Tamoxifen has been approved for this use in women age 35 years or older, and raloxifene has been approved for this use in postmenopausal women. The usual daily doses for tamoxifen and raloxifene are 20 mg and 60 mg, respectively, for 5 years.
Balance of Benefits and Harms | There is a moderate net benefit from use of tamoxifen and raloxifene to reduce the incidence of invasive breast cancer in women who are at increased risk for the disease. | The potential harms of tamoxifen and raloxifene outweigh the potential benefits for breast cancer risk reduction in women who are not at increased risk for the disease. Potential harms include thromboembolic events, endometrial cancer, and cataracts.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on risk assessment, genetic counseling, and genetic testing for BRCA-related cancer, as well as screening for breast cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Breast Cancer (Screening)

Title | Screening for Breast Cancer: Using Film Mammography
Population | Women aged 40–49 years | Women aged 50–74 years | Women aged ≥75 years
Recommendation | Individualize decision to begin biennial screening according to the patient's circumstances and values. Grade: C | Screen every 2 years. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | This recommendation applies to women aged ≥40 years who are not at increased risk by virtue of a known genetic mutation or history of chest radiation. Increasing age is the most important risk factor for most women.
Screening Tests | Standardization of film mammography has led to improved quality. Refer patients to facilities certified under the Mammography Quality Standards Act (MQSA), listed at http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfMQSA/mqsa.cfm
Timing of Screening | Evidence indicates that biennial screening is optimal. A biennial schedule preserves most of the benefit of annual screening and cuts the harms nearly in half. A longer interval may reduce the benefit.
Balance of Benefits and Harms | There is convincing evidence that screening with film mammography reduces breast cancer mortality, with a greater absolute reduction for women aged 50 to 74 years than for younger women. Harms of screening include psychological harms, additional medical visits, imaging, and biopsies in women without cancer, inconvenience due to false-positive screening results, harms of unnecessary treatment, and radiation exposure. Harms seem moderate for each age group. False-positive results are a greater concern for younger women; treatment of cancer that would not become clinically apparent during a woman's life (overdiagnosis) is an increasing problem as women age.
Rationale for No Recommendation (I Statement) | | Among women 75 years or older, evidence of benefit is lacking.
Other Relevant USPSTF Recommendations | USPSTF recommendations on screening for genetic susceptibility for breast cancer and chemoprevention of breast cancer are available at http://www.uspreventiveservicestaskforce.org.

1 The U.S. Department of Health and Human Services, in implementing the Affordable Care Act under the standard it sets out in revised Section 2713(a)(5) of the Public Health Service Act, utilizes the 2002 recommendation on breast cancer screening of the U.S. Preventive Services Task Force. For clinical summary of 2002 Recommendation, see Appendix F.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Breastfeeding

Title | Primary Care Interventions to Promote Breastfeeding
Population | Pregnant women | New mothers | The mother's partner, other family members, and friends | Infants and young children
Recommendation | Promote and support breastfeeding. Grade: B

Benefits of Breastfeeding | Mothers Less likelihood of breast and ovarian cancer | Infants Fewer ear infections, lower-respiratory-tract infections, and gastrointestinal infections | Young children Less likelihood of asthma, type 2 diabetes, and obesity
Interventions to Promote Breastfeeding | Interventions to promote and support breastfeeding have been found to increase the rates of initiation, duration, and exclusivity of breastfeeding. Consider multiple strategies, including:; - Formal breastfeeding education for mothers and families; - Direct support of mothers during breastfeeding; - Training of primary care staff about breastfeeding and techniques for breastfeeding support; - Peer support; Interventions that include both prenatal and postnatal components may be most effective at increasing breastfeeding duration. In rare circumstances, for example for mothers with HIV and infants with galactosemia, breastfeeding is not recommended. Interventions to promote breastfeeding should empower individuals to make informed choices supported by the best available evidence.
Implementation | System-level interventions with senior leadership support may be more likely to be sustained over time.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Carotid Artery Stenosis

Title | Screening for Carotid Artery Stenosis
Population | Adult general population^1^
Recommendation | Do not screen with ultrasound or other screening tests. Grade: D

Risk Assessment | The major risk factors for carotid artery stenosis (CAS) include: older age, male gender, hypertension, smoking, hypercholesterolemia, and heart disease. However, accurate, reliable risk assessment tools are not available.
Balance of Benefits and Harms | Harms outweigh benefits. In the general population, screening with carotid duplex ultrasound would result in more false-positive results than true positive results. This would lead either to surgeries that are not indicated or to confirmatory angiography. As the result of these procedures, some people would suffer serious harms (death, stroke, and myocardial infarction) that outweigh the potential benefit surgical treatment may have in preventing stroke.
Other Relevant Recommendations from the USPSTF | Adults should be screened for hypertension, hyperlipidemia, and smoking. Clinicians should discuss aspirin chemoprevention with patients at increased risk for cardiovascular disease. These recommendations and related evidence are available at http://www.uspreventiveservicestaskforce.org.

1 This recommendation applies to adults without neurological symptoms and without a history of transient ischemic attacks (TIA) or stroke. If otherwise eligible, an individual who has a carotid area TIA should be evaluated promptly for consideration of carotid endarterectomy.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Cervical Cancer

Title | Screening for Cervical Cancer
Population | Women ages 21 to 65 | Women ages 30 to 65 | Women younger than age 21 | Women older than age 65 who have had adequate prior screening and are not high risk | Women after hysterectomy with removal of the cervix and with no history of high-grade precancer or cervical cancer | Women younger than age 30
Recommendation | Screen with cytology (Pap smear) every 3 years. Grade: A | Screen with cytology every 3 years or co-testing (cytology/HPV testing) every 5 years Grade: A | Do not screen. Grade: D | Do not screen. Grade: D | Do not screen. Grade: D | Do not screen with HPV testing (alone or with cytology) Grade: D

Risk Assessment | Human papillomavirus (HPV) infection is associated with nearly all cases of cervical cancer. Other factors that put a woman at increased risk of cervical cancer include HIV infection, a compromised immune system, in utero exposure to diethylstilbestrol, and previous treatment of a high-grade precancerous lesion or cervical cancer.
Screening Tests and Interval | Screening women ages 21 to 65 years every 3 years with cytology provides a reasonable balance between benefits and harms. Screening with cytology more often than every 3 years confers little additional benefit, with large increases in harms. HPV testing combined with cytology (co-testing) every 5 years in women ages 30 to 65 years offers a comparable balance of benefits and harms, and is therefore a reasonable alternative for women in this age group who would prefer to extend the screening interval.
Timing of Screening | Screening earlier than age 21 years, regardless of sexual history, leads to more harms than benefits. Clinicians and patients should base the decision to end screening on whether the patient meets the criteria for adequate prior testing and appropriate follow-up, per established guidelines.
Interventions | Screening aims to identify high-grade precancerous cervical lesions to prevent development of cervical cancer and early-stage asymptomatic invasive cervical cancer. High-grade lesions may be treated with ablative and excisional therapies, including cryotherapy, laser ablation, loop excision, and cold knife conization. Early-stage cervical cancer may be treated with surgery (hysterectomy) or chemoradiation.
Balance of Benefits and Harms | The benefits of screening with cytology every 3 years substantially outweigh the harms. | The benefits of screening with co-testing (cytology/HPV testing) every 5 years outweigh the harms. | The harms of screening earlier than age 21 years outweigh the benefits. | The benefits of screening after age 65 years do not outweigh the potential harms. | The harms of screening after hysterectomy outweigh the benefits. | The potential harms of screening with HPV testing (alone or with cytology) outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for breast cancer and ovarian cancer, as well as genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Chlamydial Infection

Title | Screening for Chlamydial Infection
Population | Non-pregnant women | | | Pregnant women | | | Men
Population | 24 years and younger | 25 years and older | | 24 years and younger | 25 years and older | | Men
Population | Includes adolescents | Not at increased risk | At increased risk | Includes adolescents | Not at increased risk | At increased risk | Men
Recommendation | Screen if sexually active. Grade: A | Do not automatically screen. Grade: C | Screen. Grade: A | Screen. Grade: B | Do not automatically screen. Grade: C | Screen. Grade: B | No recommendation. Grade: I (Insufficient Evidence^1^)

Risk Assessment | Age: Women and men aged 24 years and younger are at greatest risk. History of: previous chlamydial infection or other sexually transmitted infections, new or multiple sexual partners, inconsistent condom use, sex work. Demographics: African-Americans and Hispanic women and men have higher prevalence rates than the general population in many communities.
Screening Tests | Nucleic acid amplification tests (NAATs) can identify chlamydial infection in asymptomatic women (non-pregnant and pregnant) and asymptomatic men. NAATs have high specificity and sensitivity and can be used with urine and vaginal swabs.
Screening Intervals | Non-Pregnant Women The optimal interval for screening is not known. The CDC recommends that women at increased risk be screened at least annually.^2^ | Pregnant Women For women 24 years and younger and older women at increased risk: Screen at the first prenatal visit. For patients at continuing risk, or who are newly at risk: Screen in the 3rd trimester. | Not applicable
Treatment | The Centers for Disease Control and Prevention has outlined appropriate treatment at: http://www.cdc.gov/STD/treatment. Test and/or treat partners of patients treated for chlamydial infection.

1 Chlamydial infection results in few sequelae in men. Therefore, the major benefit of screening men would be to reduce the likelihood that infected and untreated men would pass the infection to sexual partners. There is no evidence that screening men reduces the long-term consequences of chlamydial infection in women. Because of this lack of evidence, the USPSTF was not able to assess the balance of benefits and harms, and concluded that the evidence is insufficient to recommend for or against routinely screening men.

2 Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines, 2006. MMWR. 2006;55(No. RR-11). .

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Chronic Kidney Disease

Title | Screening for Chronic Kidney Disease
Population | Asymptomatic adults without diagnosed chronic kidney disease (CKD)
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | There is no generally accepted risk assessment tool for CKD or risk for complications of CKD. Diabetes and hypertension are well-established risk factors with strong links to CKD. Other risk factors for CKD include older age, cardiovascular disease, obesity, and family history.
Screening Tests | While there is insufficient evidence to recommend routine screening, the tests often suggested for screening that are feasible in primary care include testing the urine for protein (microalbuminuria or macroalbuminuria) and testing the blood for serum creatinine to estimate glomerular filtration rate.
Balance of Benefits and Harms | The USPSTF could not determine the balance between the benefits and harms of screening for CKD in asymptomatic adults.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for diabetes, hypertension, and obesity, as well as aspirin use for the prevention of cardiovascular disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Chronic Obstructive Pulmonary Disease

Title | Screening for Chronic Obstructive Pulmonary Disease Using Spirometry
Population | Adult general population
Recommendation | Do not screen for chronic obstructive pulmonary disease using spirometry. Grade: D

Additional Population Information | This screening recommendation applies to healthy adults who do not recognize or report respiratory symptoms to a clinician. It does not apply to individuals with a family history of alpha-1 antitrypsin deficiency.
Risk Assessment | Risk factors for COPD include:; - Current or past tobacco use.; - Exposure to occupational and environmental pollutants.; - Age 40 or older.
Screening Tests^1^ | Spirometry can be performed in a primary care physician's office or a pulmonary testing laboratory. The USPSTF did not review evidence comparing the accuracy of spirometry performed in primary care versus referral settings. For individuals who present to clinicians complaining of chronic cough, increased sputum production, wheezing, or dyspnea, spirometry would be indicated as a diagnostic test for COPD, asthma, and other pulmonary diseases.
Other Approaches to the Prevention of Pulmonary Illnesses | These services should be offered to patients regardless of COPD status:; - All current smokers should receive smoking cessation counseling and be offered pharmacologic therapies demonstrated to increase cessation rates.; - All patients 50 years of age or older should be offered influenza immunization annually.; - All patients 65 years of age or older should be offered one-time pneumococcal immunization.
Other Relevant USPSTF Recommendations | Clinicians should screen all adults for tobacco use and provide tobacco cessation interventions for those who use tobacco products. The USPSTF tobacco cessation counseling recommendation and supporting evidence are available at http://www.uspreventiveservicestaskforce.org/uspstf/uspstbac.htm.

1 The potential benefit of spirometry-based screening for COPD is prevention of one or more exacerbations by treating patients found to have an airflow obstruction previously undetected. However, even in groups with the greatest prevalence of airflow obstruction, hundreds of patients would need to be screened with spirometry to defer one exacerbation.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Cognitive Impairment

Title | Screening for Cognitive Impairment in Older Adults
Population | Community-dwelling adults who are older than age 65 years and have no signs or symptoms of cognitive impairment
Recommendation | No recommendation. Grade: I statement

Risk Assessment | Increasing age is the strongest known risk factor for cognitive impairment. Other reported risk factors for cognitive impairment include cardiovascular risk factors (such as diabetes, tobacco use, hypercholesterolemia, and hypertension), head trauma, learning disabilities (such as Down syndrome), depression, alcohol abuse, physical frailty, low education level, low social support, and having never been married.
Screening Tests | Screening tests for cognitive impairment in the clinical setting generally include asking patients to perform a series of tasks that assess 1 or more cognitive domains (memory, attention, language, and visuospatial or executive functioning). The most widely studied instrument is the Mini-Mental State Examination. Other instruments with more limited evidence include the Clock Draw Test, Mini-Cog, Memory Impairment Screen, Abbreviated Mental Test, Short Portable Mental Status Questionnaire, Free and Cued Selective Reminding Test, 7-Minute Screen, Telephone Interview for Cognitive Status, and Informant Questionnaire on Cognitive Decline in the Elderly.
Treatment | Pharmacologic treatments approved by the U.S. Food and Drug Administration include acetylcholinesterase inhibitors and memantine. Nonpharmacologic interventions include cognitive training, lifestyle behavioral interventions, exercise, educational interventions, and multidisciplinary care interventions. Some interventions focus on the caregiver and aim to improve caregiver morbidity and delay institutionalization of persons with dementia.
Balance of Benefits and Harms | The evidence on screening for cognitive impairment is lacking, and the balance of benefits and harms cannot be determined.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations related to several of the risk factors for cognitive impairment, including counseling on tobacco cessation, alcohol use, healthful diet, physical activity, and falls prevention and screening for high cholesterol, hypertension, and depression. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Colorectal Cancer

Title | Screening for Colorectal Cancer
Population^1^ | Adults age 50 to 75 years | Adults age 76 to 85 years | Adults older than 85
Recommendation | Screen with high sensitivity fecal occult blood testing (FOBT), sigmoidoscopy, or colonoscopy. Grade: A | Do not automatically screen. Grade: C | Do not screen. Grade: D
| For all populations, evidence is insufficient to assess the benefits and harms of screening with computerized tomography colonography (CTC) and fecal DNA testing. Grade: I (Insufficient Evidence)

Screening Tests | High sensitivity FOBT, sigmoidoscopy with FOBT, and colonoscopy are effective in decreasing colorectal cancer mortality. The risks and benefits of these screening methods vary. Colonoscopy and flexible sigmoidoscopy (to a lesser degree) entail possible serious complications.
Screening Test Intervals | Intervals for recommended screening strategies:; - Annual screening with high-sensitivity fecal occult blood testing; - Sigmoidoscopy every 5 years, with high-sensitivity fecal occult blood testing every 3 years; - Screening colonoscopy every 10 years
Balance of Benefits and Harms | The benefits of screening outweigh the potential harms for 50- to 75-year-olds. | The likelihood that detection and early intervention will yield a mortality benefit declines after age 75 because of the long average time between adenoma development and cancer diagnosis.
Implementation | Focus on strategies that maximize the number of individuals who get screened. Practice shared decisionmaking; discussions with patients should incorporate information on test quality and availability. Individuals with a personal history of cancer or adenomatous polyps are followed by a surveillance regimen, and screening guidelines are not applicable.
Other Relevant USPSTF Recommendations | The USPSTF recommends against the use of aspirin or nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer. This recommendation is available at http://www.uspreventiveservicestaskforce.org.

1 These recommendations do not apply to individuals with specific inherited syndromes (Lynch Syndrome or Familial Adenomatous Polyposis) or those with inflammatory bowel disease.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Coronary Heart Disease (Risk Assessment, Nontraditional Risk Factors)

Title | Using Nontraditional Risk Factors In Coronary Heart Disease Risk Assessment
Population | Asymptomatic men and women with no history of coronary heart disease (CHD), diabetes, or any CHD risk equivalent
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | This recommendation applies to adult men and women classified at intermediate 10-year risk for CHD (10% to 20%) by traditional risk factors.
Importance | Coronary heart disease (CHD) is the most common cause of death in adults in the United States. Treatment to prevent CHD events by modifying risk factors is currently based on the Framingham risk model. If the classification of individuals at intermediate risk could be improved by using additional risk factors, treatment to prevent CHD might be targeted more effectively. Risk factors not currently part of the Framingham model (nontraditional risk factors) include high sensitivity C-reactive protein (hs-CRP), ankle-brachial index (ABI), leukocyte count, fasting blood glucose level, periodontal disease, carotid intima-media thickness, electron beam computed tomography, homocysteine level, and lipoprotein(a) level.
Balacne of Benefits and Harms | There is insufficient evidence to determine the percentage of intermediate-risk individuals who would be reclassified by screening with nontraditional risk factors, other than hs-CRP and ABI. For individuals reclassified as high-risk on the basis of hs-CRP or ABI scores, data are not available to determine whether they benefit from additional treatments. Little evidence is available to determine the harms of using nontraditional risk factors in screening. Potential harms include lifelong use of medications without proven benefit and psychological and other harms from being misclassified in a higher risk category.
Suggestions for practice | Clinicians should continue to use the Framingham model to assess CHD risk and guide risk-based preventive therapy. Adding nontraditional risk factors to CHD assessment would require additional patient and clinical staff time and effort. Routinely screening with nontraditional risk factors could result in lost opportunities to provide other important health services of proven benefit.
Other Relevant USPSTF Recommendations | USPSTF recommendations on risk assessment for CHD, the use of aspirin to prevent cardiovascular disease, and screening for high blood pressure can be accessed at http://www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Coronary Heart Disease (Electrocardiography)

Title | Screening for Coronary Heart Disease with Electrocardiography
Population | Asymptomatic adults at low risk for coronary heart disease (CHD) events | Asymptomatic adults at intermediate or high risk for CHD events
Recommendation | Do not screen with resting or exercise electrocardiography (ECG). Grade: D | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Several factors are associated with a higher risk for CHD events, including older age, male sex, high blood pressure, smoking, abnormal lipid levels, diabetes, obesity, and sedentary lifestyle. Calculators are available to ascertain a person's 10-year risk for a CHD event. Persons with a 10-year risk >20% are considered to be high-risk, those with a 10-year risk <10% are considered to be low-risk, and those in the 10%-20% range are considered to be intermediate-risk.
Screening Tests | Several abnormalities on resting and exercise ECG are associated with an increased risk for a serious CHD event. However, the incremental information offered by screening asymptomatic adults at low risk for a CHD event with resting or exercise ECG (beyond that obtained with conventional CHD risk factors) is highly unlikely to result in changes in risk stratification that would prompt interventions and ultimately reduce CHD-related events.
Balance of Benefits and Harms | The potential harms of screening for CHD with exercise or resting ECG equal or exceed the potential benefits in this population. | The USPSTF could not determine the balance between the benefits and harms of screening for CHD with resting or exercise ECG in this population.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for carotid artery stenosis, high blood pressure, lipid disorders, peripheral arterial disease, and obesity. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Depression in Adults

Title | Screening for Depression in Adults
Population | Nonpregnant adults 18 years or older
Recommendation | Screen when staff-assisted depression care supports^1^ are in place to assure accurate diagnosis, effective treatment, and followup. Grade: B | Do not automatically screen when staff-assisted depression care supports^1^ are not in place. Grade: C

Risk Assessment | Persons at increased risk for depression are considered at risk throughout their lifetime. Groups at increased risk include persons with other psychiatric disorders, including substance misuse; persons with a family history of depression; persons with chronic medical diseases; and persons who are unemployed or of lower socioeconomic status. Also, women are at increased risk compared with men. However, the presence of risk factors alone cannot distinguish depressed patients from nondepressed patients.
Screening Tests | Simple screening questions may perform as well as more complex instruments. Any positive screening test result should trigger a full diagnostic interview using standard diagnostic criteria.
Timing of Screening | The optimal interval for screening is unknown. In older adults, significant depressive symptoms are associated with common life events, including medical illness, cognitive decline, bereavement, and institutional placement in residential or inpatient settings.
Balance of Benefits and Harms | | Limited evidence suggests that screening for depression in the absence of staff-assisted depression care does not improve depression outcomes.
Suggestions for Practice | “Staff-assisted depression care supports” refers to clinical staff that assists the primary care clinician by providing some direct depression care and/or coordination, case management, or mental health treatment.
Relevant USPSTF Recommendations | Related USPSTF recommendations on screening for suicidality and screening children and adolescents for depression are available at http://www.uspreventiveservicestaskforce.org.

1 Go to the Suggestions for Practice section of this figure for further explanation.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Diabetes Mellitus

Title | Screening for Type 2 Diabetes Mellitus in Adults
Population | Asymptomatic adults with sustained blood pressure greater than 135/80 mm Hg | Asymptomatic adults with sustained blood pressure 135/80 mm Hg or lower
Recommendation | Screen for type 2 diabetes mellitus. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | These recommendations apply to adults with no symptoms of type 2 diabetes mellitus or evidence of possible complications of diabetes. Blood pressure measurement is an important predictor of cardiovascular complications in people with type 2 diabetes mellitus. The first step in applying this recommendation should be measurement of blood pressure (BP). Adults with treated or untreated BP >135/80 mm Hg should be screened for diabetes.
Screening Tests | Three tests have been used to screen for diabetes:; - Fasting plasma glucose (FPG).; - 2-hour postload plasma.; - Hemoglobin A1c.; The American Diabetes Association (ADA) recommends screening with FPG, defines diabetes as FPG ≥ 126 mg/dL, and recommends confirmation with a repeated screening test on a separate day.
Screening Intervals | The optimal screening interval is not known. The ADA, on the basis of expert opinion, recommends an interval of every 3 years.
Suggestions for practice regarding insufficient evidence | When BP is ≤ 135/80 mm Hg, screening may be considered on an individual basis when knowledge of diabetes status would help inform decisions about coronary heart disease (CHD) preventive strategies, including consideration of lipid-lowering agents or aspirin. To determine whether screening would be helpful on an individual basis, information about 10-year CHD risk must be considered. For example, if CHD risk without diabetes was 17% and risk with diabetes was >20%, screening for diabetes would be helpful because diabetes status would determine lipid treatment. In contrast, if risk without diabetes was 10% and risk with diabetes was 15%, screening would not affect the decision to use lipid-lowering treatment.
Other relevant information from the USPSTF and the Community Preventive Services Task Force | Evidence and USPSTF recommendations regarding blood pressure, diet, physical activity, and obesity are available at http://www.uspreventiveservicestaskforce.org. The reviews and recommendations of the Community Preventive Services Task Force may be found at http://www.thecommunityguide.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Falls in Older Adults

Title | Prevention of Falls in Community-Dwelling Older Adults
Population | Community-dwelling adults aged 65 years and older who are at increased risk for falls | Community-dwelling adults aged 65 years and older
Recommendation | Provide intervention consisting of exercise or physical therapy and/or vitamin D supplementation to prevent falls. Grade: B | Do not automatically perform an in-depth multifactorial risk assessment with comprehensive management of identified risks to prevent falls. Grade: C

Risk Assessment | Primary care clinicians can consider the following factors to identify older adults at increased risk for falls: a history of falls, a history of mobility problems, and poor performance on the timed Get-Up-and-Go test.
Interventions | Effective exercise and physical therapy interventions include group classes and at-home physiotherapy strategies and range in intensity from very low (≤9 hours) to high (>75 hours). Benefit from vitamin D supplementation occurs by 12 months; the efficacy of treatment of shorter duration is unknown. The recommended daily allowance for vitamin D is 600 IU for adults aged 51 to 70 years and 800 IU for adults older than 70 years. Comprehensive multifactorial assessment and management interventions include assessment of multiple risk factors for falls and providing medical and social care to address factors identified during the assessment. In determining whether this service is appropriate in individual cases, patients and clinicians should consider the balance of benefits and harms on the basis of the circumstances of prior falls, medical comorbid conditions, and patient values.
Balance of Benefits and Harms | Exercise or physical therapy and vitamin D supplementation have a moderate benefit in preventing falls in older adults. | Multifactorial risk assessment with comprehensive management of identified risks has at least a small benefit in preventing falls in older adults.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for osteoporosis. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Folic Acid Supplementation

Title | Folic Acid for the Prevention of Neural Tube Defects
Population | Women planning a pregnancy or capable of becoming pregnant
Recommendation | Take a daily vitamin supplement containing 0.4 to 0.8 mg (400 to 800 μg) of folic acid. Grade: A

Risk Assessment | Risk factors include:; - A personal or family history of a pregnancy affected by a neural tube defect; - The use of certain antiseizure medications; - Mutations in folate-related enzymes; - Maternal diabetes; - Maternal obesity; Note: This recommendation does not apply to women who have had a previous pregnancy affected by neural tube defects or women taking certain antiseizure medicines. These women may be advised to take higher doses of folic acid.
Timing of Medication | Start supplementation at least 1 month before conception. Continue through first 2 to 3 months of pregnancy.
Recommendations of Others | ACOG, AAFP, and most other organizations recommend 4 mg/d for women with a history of a pregnancy affected by a neural tube defect.

Abbreviations: AAFP = American Academy of Family Physicians; ACOG = American College of Obstetricians and Gynecologists.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Genital Herpes

Time | Screening for Genital Herpes
Population | Asymptomatic pregnant women | Asymptomatic adolescents and adults
Recommendation | Do not screen for herpes simplex virus. Grade: D | Do not screen for herpes simplex virus. Grade: D

Screening Tests | Methods for detecting herpes simplex virus include viral culture, polymerase chain reaction, and antibody-based tests, such as the western blot assay and type-specific glycoprotein G serological tests.
Interventions | There is limited evidence that the use of antiviral therapy in women with a history of recurrent infection, or performance of cesarean delivery in women with active herpes lesions at the time of delivery, decreases neonatal herpes infection. There is also limited evidence of the safety of antiviral therapy in pregnant women and neonates. | Antiviral therapy improves health outcomes in symptomatic persons (e.g., those with multiple recurrences); however, there is no evidence that the use of antiviral therapy improves health outcomes in those with asymptomatic infection. There are multiple efficacious regimens that may be used to prevent the recurrence of clinical genital herpes.
Balance of Benefits and Harms | The potential harms of screening asymptomatic pregnant women include false-positive test results, labeling, and anxiety, as well as false-negative tests and false reassurance, although these potential harms are not well studied. The USPSTF determined that there are no benefits associated with screening, and therefore the potential harms outweigh the benefits. | The potential harms of screening asymptomatic adolescents and adults include false-positive test results, labeling, and anxiety, although these potential harms are not well studied. The USPSTF determined the benefits of screening are minimal, at best, and the potential harms outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for chlamydia, gonorrhea, HIV, and several other sexually transmitted infections. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Gestational Diabetes Mellitus

Title | Screening for Gestational Diabetes Mellitus
Population | Asymptomatic pregnant women after 24 weeks of gestation | Asymptomatic pregnant women before 24 weeks of gestation
Recommendation | Screen for gestational diabetes mellitus (GDM). Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Risk factors that increase a woman's risk for developing GDM include obesity, increased maternal age, history of GDM, family history of diabetes, and belonging to an ethnic group with increased risk of developing type 2 diabetes mellitus (Hispanic, Native American, South or East Asian, African American, or Pacific Islands descent).
Screening Tests | There are 2 strategies used to screen for gestational diabetes in the United States. In the 2-step approach, the 50-g oral glucose challenge test is administered between 24 and 28 weeks of gestation in a nonfasting state. If the screening threshold is met or exceeded (7.22 mmol/L [130 mg/dL], 7.50 mmol/L [135 mg/dL], or 7.77 mmol/L [140 mg/dL]), patients receive the oral glucose tolerance test. A diagnosis of GDM is made when 2 or more glucose levels meet or exceed the specified glucose thresholds. In the 1-step approach, a 75-g glucose load is administered after fasting and plasma glucose levels are evaluated after 1 and 2 hours. GDM is diagnosed if 1 glucose value falls at or above the specified glucose threshold. Other methods of screening include fasting plasma glucose and screening based on risk factors. However, there is limited evidence on these alternative screening approaches.
Treatment | Initial treatment includes moderate physical activity, dietary changes, support from diabetes educators and nutritionists, and glucose monitoring. If the patient's glucose is not controlled after these initial interventions, she may be prescribed medication (either insulin or oral hypoglycemic agents), undergo increased surveillance in prenatal care, and have changes in delivery management.
Balance of Benefits and Harms | There is a moderate net benefit to screening for GDM after 24 weeks of gestation to reduce maternal and fetal complications. | The evidence for screening for GDM before 24 weeks of gestation is insufficient, and the balance of benefits and harms of screening cannot be determined.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for type 2 diabetes. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Glaucoma

Title | Screening for Glaucoma
Population | Adults without vision symptoms who are seen in primary care
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Important risk factors for open-angle glaucoma are increased intraocular pressure, older age, family history of glaucoma, and African American race.
Screening Tests | Diagnosis of glaucoma is usually made on the basis of several tests that, when combined, evaluate the biologic structure and function of the optic nerve and intraocular pressure. Most tests that are available in a primary care setting do not have acceptable accuracy to detect glaucoma.
Treatment | The immediate physiologic goal and measure of effect of primary treatment of glaucoma is reduction in intraocular pressure. Treatments that are effective in reducing intraocular pressure include medications, laser therapy, and surgery. However, these treatments have potential harms, and their effectiveness in reducing patient-perceived impairment in vision-related function is uncertain.
Balance of Benefits and Harms | Evidence on the accuracy of screening tests, especially in primary care settings, and the benefits of screening or treatment to delay or prevent visual impairment or improve quality of life is inadequate. Therefore, the overall certainty of the evidence is low, and the USPSTF is unable to determine the balance of benefits and harms of screening for glaucoma in asymptomatic adults.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for impaired visual acuity in older adults. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Gonorrhea

Title | Screening for Gonorrhea
Population | Sexually active women, including those who are pregnant, who are at increased risk for infection | Men who are at increased risk for infection | Men and women who are at low risk for infection | Pregnant women who are not at increased risk for infection
Recommendation | Screen for gonorrhea. Grade: B | No recommendation. Grade: I (Insufficient Evidence) | Do not screen for gonorrhea. Grade: D | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Women and men younger than age 25 years—including sexually active adolescents—are at highest risk for gonorrhea infection. Risk factors for gonorrhea include a history of previous gonorrhea infection, other sexually transmitted infections, new or multiple sexual partners, inconsistent condom use, sex work, and drug use. Risk factors for pregnant women are the same as for non-pregnant women.
Screening Tests | Vaginal culture is an accurate screening test when transport conditions are suitable. Newer screening tests, including nucleic acid amplification and hybridization tests, have demonstrated improved sensitivity and comparable specificity when compared with cervical culture. Some newer tests can be used with urine and vaginal swabs, which enables screening when a pelvic examination is not performed.
Timing of Screening | Screening is recommended at the first prenatal visit for pregnant women who are in a high-risk group for gonorrhea infection. For pregnant women who are at continued risk, and for those who acquire a new risk factor, a second screening should be conducted during the third trimester. The optimal interval for screening in the non-pregnant population is not known.
Interventions | Genital gonorrhea infection in men and women, including pregnant women, may be treated with a third-generation cephalosporin. Because of increased prevalence of resistant organisms, fluoroquinolones should not be used to treat gonorrhea. Current guidelines for treating gonorrhea infection are available from the Centers for Disease Control and Prevention (http://www.cdc.gov/std/treatment).
Balance of Benefits and Harms | The USPSTF concluded that the benefits of screening women at increased risk for gonorrhea infection outweigh the potential harms. | The USPSTF could not determine the balance of benefits and harms of screening for gonorrhea in men at increased risk for infection. | Given the low prevalence of gonorrhea infection in the general population, the USPSTF concluded that the potential harms of screening in low-prevalence populations outweigh the benefits. | The USPSTF could not determine the balance between the benefits and harms of screening for gonorrhea in pregnant women who are not at increased risk for infection.
Other Relevant USPSTF Recommendations | The USPSTF has also made a recommendation on ocular prophylaxis in newborns for gonococcal ophthalmia neonatorum. This recommendation is available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Healthful Diet and Physical Activity

Title | Behavioral Counseling Interventions to Promote A Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults
Population | General adult population without a known diagnosis of hypertension, diabetes, hyperlipidemia, or cardiovascular disease
Recommendation | Although the correlation among healthful diet, physical activity, and the incidence of cardiovascular disease is strong, existing evidence indicates that the health benefit of initiating behavioral counseling in the primary care setting to promote a healthful diet and physical activity is small. Clinicians may choose to selectively counsel patients rather than incorporate counseling into the care of all adults in the general population. [underlined: Considerations:]Issues to consider include other risk factors for cardiovascular disease, patient readiness for change, social support and community resources that support behavioral change, and other health care and preventive service priorities. [underlined: Potential Harms:] Harms may include the lost opportunity to provide other services with a greater health effect. Grade: C

Risk Assessment | If an individual's risk for cardiovascular disease is uncertain, there are several calculators and models available to quantify a person's 10-year risk for cardiac events, such as the Framingham-based Adult Treatment Panel III calculator (available at http://hp2010.nhlbihin.net/atpiii/calculator.asp). Generally, persons with a 10-year risk greater than 20% are considered to be high-risk, those with a 10-year risk less than 10% are considered to be low-risk, and those in the 10% to 20% range are considered to be intermediate-risk.
Interventions | Medium- or high-intensity behavioral interventions to promote a healthful diet and physical activity may be provided to individual patients in primary care settings or in other sectors of the health care system after referral from a primary care clinician. In addition, clinicians may offer healthful diet and physical activity interventions by referring the patient to community-based organizations. Strong linkages between the primary care setting and community-based resources may improve the delivery of these services.
Balance of Benefits and Harms | The USPSTF concludes with moderate certainty that medium- or high-intensity primary care behavioral counseling interventions to promote a healthful diet and physical activity have a small net benefit in adult patients without cardiovascular disease, hypertension, hyperlipidemia, or diabetes.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for carotid artery stenosis, coronary heart disease, high blood pressure, lipid disorders, peripheral arterial disease, and obesity. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Hearing Loss in Older Adults

Title | Screening for Hearing Loss in Older Adults
Population | Asymptomatic adults aged 50 years or older
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Increasing age is the most important risk factor for hearing loss. Other risk factors include a history of exposure to loud noises or ototoxic agents, including occupational exposures, previous recurrent inner ear infections, genetic factors, and certain systemic diseases, such as diabetes.
Screening Tests | Various screening tests are used in primary care settings to detect hearing loss in adults, including:; - Whispered voice test; - Finger rub test; - Watch tick test; - Single-item screening (for example, asking “Do you have difficulty with your hearing?”); - Multiple-item patient questionnaire (for example, Hearing Handicap Inventory for the Elderly—Screening Version); - Handheld audiometer
Interventions | Hearing aids can improve self-reported hearing, communication, and social functioning for some adults with age-related hearing loss.
Balance of Benefits and Harms | There is inadequate evidence to determine the balance of benefits and harms of screening for hearing loss in adults aged 50 years or older.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Hemochromatosis

Title | Screening for Hemochromatosis
Population | Asymptomatic general population
Recommendation | Do not screen for hereditary hemochromatosis. Grade: D

Risk Assessment | Clinically recognized hereditary hemochromatosis is primarily associated with mutations on the hemochromatosis (HFE) gene. Although this is a relatively common mutation in the U.S. population, only a small subset will develop symptoms of hemochromatosis. An even smaller proportion of these individuals will develop advanced stages of clinical disease.
Screening Tests | Genetic screening for HFE mutations can accurately identify individuals at risk for hereditary hemochromatosis. However, identifying an individual with the genotypic predisposition does not accurately predict the future risk for disease manifestation.
Interventions | Therapeutic phlebotomy is the main treatment for hereditary hemochromatosis. Phlebotomy is generally thought to have few side effects.
Balance of Benefits and Harms | - Screening could lead to identification of a large number of individuals who possess the high-risk genotype but may never manifest the clinical disease. This may result in unnecessary surveillance and diagnostic procedures, labeling, anxiety, and, potentially, unnecessary treatments.; - There is poor evidence that early therapeutic phlebotomy improves morbidity and mortality in individuals with screening-detected versus clinically-detected hemochromatosis.; - The USPSTF concluded that the potential harms of genetic screening for hereditary hemochromatosis outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on genetic testing for mutations in the breast cancer susceptibility gene to predict breast and ovarian cancer susceptibility. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Hepatitis B Virus Infection (Pregnant Women)

Title | Screening for Hepatitis B Virus Infection in Pregnancy
Population | All pregnant women
Recommendation | Screen for hepatitis B virus (HBV) at the first prenatal visit. Grade: A

Screening Tests | Serologic identification of hepatitis B surface antigen (HBsAg). Reported sensitivity and specificity are greater than 98%.
Timing of Screening | Order HBsAg testing at the first prenatal visit. Re-screen women with unknown HBsAg status or new or continuing risk factors at admission to hospital, birth center, or other delivery setting.
Interventions | Administer hepatitis B vaccine and hepatitis B immune globulin to HBV-exposed infants within 12 hours of birth. Refer women who test positive for counseling and medical management. Counseling should include information about how to prevent transmission to sexual partners and household contacts. Reassure patients that breastfeeding is safe for infants who receive appropriate prophylaxis.
Implementation | Establish systems for timely transfer of maternal HBsAg test results to the labor and delivery and newborn medical records.
Other Relevant USPSTF Recommendations | USPSTF recommendations on the screening of pregnant women for other infections, including asymptomatic bacteriuria, bacterial vaginosis, chlamydia, HIV, and syphilis, can be found at http://www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Hepatitis C Virus Infection

Title | Screening for Hepatitis C Virus Infection in Adults
Population | Persons at high risk for infection and adults born between 1945 and 1965
Recommendation | Screen for hepatitis C virus (HCV) infection. Grade: B

Risk Assessment | The most important risk factor for HCV infection is past or current injection drug use. Additional risk factors include receiving a blood transfusion before 1992, long-term hemodialysis, being born to an HCV-infected mother, incarceration, intranasal drug use, getting an unregulated tattoo, and other percutaneous exposures. Adults born between 1945 and 1965 are more likely to be diagnosed with HCV infection, either because they received a blood transfusion before the introduction of screening in 1992 or because they have a history of other risk factors for exposure decades earlier.
Screening Tests | Anti-HCV antibody testing followed by confirmatory polymerase chain reaction testing accurately identifies patients with chronic HCV infection. Various noninvasive tests with good diagnostic accuracy are possible alternatives to liver biopsy for diagnosing fibrosis or cirrhosis.
Screening Interval | Persons with continued risk for HCV infection (such as injection drug users) should be screened periodically. Evidence on how often screening should occur in these persons is lacking. Adults born between 1945 and 1965 and persons who are at risk because of potential exposure before universal blood screening need only be screened once.
Treatment | Antiviral treatment prevents long-term health complications of HCV infection (such as cirrhosis, liver failure, and hepatocellular carcinoma). The combination of pegylated interferon (a-2a or a-2b) and ribavirin is the standard treatment for HCV infection. In 2011, the U.S. Food and Drug Administration approved the protease inhibitors boceprevir and telaprevir for the treatment of HCV genotype 1 infection (the predominant genotype in the United States).
Balance of Benefits and Harms | On the basis of the accuracy of HCV antibody testing and the availability of effective interventions for persons with HCV infection, the USPSTF concludes that there is a moderate net benefit to screening in populations at high risk for infection. The USPSTF concludes that there is also a moderate net benefit to 1-time screening in all adults in the United States born between 1945 and 1965.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for hepatitis B virus infection in adolescents, adults, and pregnant women. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## High Blood Pressure in Adults

Title | Screening for High Blood Pressure in adults
Population | Adult general population^1^
Recommendation | Screen for high blood pressure. Grade: A

Screening Tests | High blood pressure (hypertension) is usually defined in adults as: systolic blood pressure (SBP) of 140 mm Hg or higher, or diastolic blood pressure (DBP) of 90 mm Hg or higher. Due to variability in individual blood pressure measurements, it is recommended that hypertension be diagnosed only after 2 or more elevated readings are obtained on at least 2 visits over a period of 1 to several weeks.
Screening Intervals | The optimal interval for screening adults for hypertension is not known. The Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC 7) recommends:; - Screening every 2 years with BP <120/80.; - Screening every year with SBP of 120–139 mmHg or DBP of 80–90 mmHg.
Treatment | A variety of pharmacological agents are available to treat hypertension. JNC 7 guidelines for treatment of hypertension can be accessed at http://www.nhlbi.nih.gov/guidelines/hypertension/jncintro.htm. The following non-pharmacological therapies are associated with reductions in blood pressure:; - Reduction of dietary sodium intake.; - Potassium supplementation.; - Increased physical activity, weight loss.; - Stress management.; - Reduction of alcohol intake.
Other Relevant USPSTF Recommendations | Adults with hypertension should be screened for diabetes. Adults should be screened for hyperlipidemia (depending on age, sex, risk factors) and smoking. Clinicians should discuss aspirin chemoprevention with patients at increased risk for cardiovascular disease. These recommendations and related evidence are available at http://www.uspreventiveservicestaskforce.org.

1 This recommendation applies to adults without known hypertension.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *HIV Infection

Title | Screening for HIV
Population | Adolescents and adults aged 15 to 65 years, younger adolescents and older adults at increased risk for infection, and pregnant women
Recommendation | Screen for HIV infection. Grade: A

Risk Assessment | Men who have sex with men and active injection drug users are at very high risk for new HIV infection. Other persons at high risk include those who have acquired or request testing for other sexually transmitted infections. Behavioral risk factors for HIV infection include:; - Having unprotected vaginal or anal intercourse; - Having sexual partners who are HIV-infected, bisexual, or injection drug users; - Exchanging sex for drugs or money; The USPSTF recognizes that the above categories are not mutually exclusive, the degree of sexual risk is on a continuum, and individuals may not be aware of their sexual partners' risk factors for HIV infection.
Screening Tests | The conventional serum test for diagnosing HIV infection is repeatedly reactive immunoassay, followed by confirmatory Western blot or immunofluorescent assay. Conventional HIV test results are available within 1 to 2 days from most commercial laboratories. Rapid HIV testing may use either blood or oral fluid specimens and can provide results in 5 to 40 minutes; however, initial positive results require confirmation with conventional methods. Other U.S. Food and Drug Administration-approved tests for detection and confirmation of HIV infection include combination tests (for p24 antigen and HIV antibodies) and qualitative HIV-1 RNA.
Interventions | At present, there is no cure for chronic HIV infection. However, appropriately timed interventions in HIV-positive persons can reduce risks for clinical progression, complications or death from the disease, and disease transmission. Effective interventions include antiretroviral therapy (ART) (specifically, the use of combined ART), immunizations, and prophylaxis for opportunistic infections.
Balance of Benefits and Harms | The net benefit of screening for HIV infection in adolescents, adults, and pregnant women is substantial.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on behavioral counseling to prevent sexually transmitted infections. This recommendation is available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Illicit Drug Use

Title | Screening for Illicit Drug Use
Population | Adolescents^1^, adults, and pregnant women not previously identified as users of illicit drugs
Recommendation | No recommendation. Grade I: (Insufficient Evidence)

Screening Tests | Toxicologic tests of blood or urine can provide objective evidence of drug use, but do not distinguish occasional users from impaired drug users. Valid and reliable standardized questionnaires are available to screen adolescents and adults for drug use or misuse. There is insufficient evidence to evaluate the clinical utility of these instruments when widely applied in primary care settings.
Balance of Benefits and Harms | The USPSTF concludes that for adolescents, adults, and pregnant women, the evidence is insufficient to determine the benefits and harms of screening for illicit drug use.
Suggestions for Practice | Clinicians should be alert to the signs and symptoms of illicit drug use in patients.
Treatment | More evidence is needed on the effectiveness of primary care office-based treatments for illicit drug use/dependence.
Other Relevant USPSTF Recommendations | The USPSTF recommendation for screening and counseling interventions to reduce alcohol misuse by adults and pregnant women can be found at http://www.uspreventiveservicestaskforce.org/uspstf/uspsdrin.htm.

1 For adolescents, see also Illicit and Prescription Drug Use in Children and Adolescents, Counseling

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Impaired Visual Acuity in Older Adults^1^ 1 This recommendation does not cover screening for glaucoma.

Title | Screening for Impaired Visual Acuity in Older Adults 1
Population | Adults age 65 and older
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Older age is an important risk factor for most types of visual impairment. Additional risk factors include:; - Smoking, alcohol use, exposure to ultraviolet light, diabetes, corticosteroids, and black race (for cataracts).; - Smoking, family history, and white race (for age-related macular degeneration).
Screening Tests | Visual acuity testing (for example, the Snellen eye chart) is the usual method for screening for impairment of visual acuity in the primary care setting. Screening questions are not as accurate as a visual acuity test.
Balance of Benefits and Harms | There is no direct evidence that screening for vision impairment in older adults in primary care settings is associated with improved clinical outcomes. There is evidence that early treatment of refractive error, cataracts, and age-related macular degeneration may lead to harms that are small. The magnitude of net benefit for screening cannot be calculated because of a lack of evidence.
Other Relevant USPSTF Recommendations | Recommendations on screening for glaucoma and on screening for hearing loss in older adults can be accessed at http://www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Intimate Partner Violence and Elderly Abuse

Title | Screening for Intimate Partner Violence and Abuse of Elderly and Vulnerable Adults
Population | Asymptomatic women of childbearing age | Elderly or vulnerable adults
Recommendation | Screen women for intimate partner violence (IPV), and provide or refer women who screen positive to intervention services. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | While all women are at potential risk for abuse, factors that elevate risk include young age, substance abuse, marital difficulties, and economic hardships.
Interventions | Adequate evidence from randomized trials support a variety of interventions for women of childbearing age that can be delivered or referred by primary care, including counseling, home visits, information cards, referrals to community services, and mentoring support. Depending on the type of intervention, these services may be provided by clinicians, nurses, social workers, nonclinician mentors, or community workers.
Balance of Benefits and Harms | Screening and interventions for IPV in women of childbearing age are associated with moderate health improvements through the reduction of exposure to abuse, physical and mental harms, and mortality. The associated harms are deemed no greater than small. Therefore, the overall net benefit is moderate. | The USPSTF was not able to estimate the magnitude of net benefit for screening all elderly or vulnerable adults (i.e., adults who are physically or mentally dysfunctional) for abuse and neglect because there were no studies on the accuracy, effectiveness, or harms of screening in this population.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for depression in adults and screening and counseling to reduce alcohol misuse in adults. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Lipid Disorders in Adults

Title | Screening for Lipid Disorders in Adults
Population | - Men age 35 years and older; - Women age 45 years and older who are at increased risk for coronary heart disease (CHD) | - Men ages 20 to 35 years who are at increased risk for CHD; - Women ages 20 to 45 years who are at increased risk for CHD | - Men ages 20 to 35 years; - Women age 20 years and older who are not at increased risk for CHD
Recommendation | Screen for lipid disorders. Grade: A | Screen for lipid disorders. Grade: B | No recommendation for or against screening Grade: C

Risk Assessment | Consideration of lipid levels along with other risk factors allows for an accurate estimation of CHD risk. Risk factors for CHD include diabetes, history of previous CHD or atherosclerosis, family history of cardiovascular disease, tobacco use, hypertension, and obesity (body mass index ≥30 kg/m^2^).
Screening Tests | The preferred screening tests for dyslipidemia are measuring serum lipid (total cholesterol, high-density and low-denisty lipoprotein cholesterol) levels in non-fasting or fasting samples. Abnormal screening results should be confirmed by a repeated sample on a separate occasion, and the average of both results should be used for risk assessment.
Timing of Screening | The optimal interval for screening is uncertain. Reasonable options include every 5 years, shorter intervals for people who have lipid levels close to those warranting therapy, and longer intervals for those not at increased risk who have had repeatedly normal lipid levels. An age at which to stop screening has not been established. Screening may be appropriate in older people who have never been screened; repeated screening is less important in older people because lipid levels are less likely to increase after age 65 years.
Interventions | Drug therapy is usually more effective than diet alone in improving lipid profiles, but choice of treatment should consider overall risk, costs of treatment, and patient preferences. Guidelines for treating lipid disorders are available from the National Cholesterol Education Program of the National Institutes of Health (http://www.nhlbi.nih.gov/about/ncep/).
Balance of Benefits and Harms | The benefits of screening for and treating lipid disorders in men age 35 and older and women age 45 and older at increased risk for CHD substantially outweigh the potential harms. | The benefits of screening for and treating lipid disorders in young adults at increased risk for CHD moderately outweigh the potential harms. | The net benefits of screening for lipid disorders in young adults not at increased risk for CHD are not sufficient to make a general recommendation.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for lipid disorders in children and screening for carotid artery stenosis, coronary heart disease, high blood pressure, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Lung Cancer

Title | Screening for Lung Cancer
Population | Asymptomatic adults aged 55 to 80 years who have a 30 pack-year smoking history and currently smoke or have quit smoking within the past 15 years
Recommendation | Screen annually for lung cancer with low-dose computed tomography. Discontinue screening when the patient has not smoked for 15 years. Grade: B

Risk Assessment | Age, total cumulative exposure to tobacco smoke, and years since quitting smoking are the most important risk factors for lung cancer. Other risk factors include specific occupational exposures, radon exposure, family history, and history of pulmonary fibrosis or chronic obstructive lung disease.
Screening Tests | Low-dose computed tomography has high sensitivity and acceptable specificity for detecting lung cancer in high-risk persons and is the only currently recommended screening test for lung cancer.
Treatment | Non-small cell lung cancer is treated with surgical resection when possible and also with radiation and chemotherapy.
Balance of Benefits and Harms | Annual screening for lung cancer with low-dose computed tomography is of moderate net benefit in asymptomatic persons who are at high risk for lung cancer based on age, total cumulative exposure to tobacco smoke, and years since quitting smoking.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on counseling and interventions to prevent tobacco use and tobacco-caused disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Menopausal Hormone Therapy

Title | Menopausal Hormone Therapy for the Primary Prevention of Chronic Conditions
Population | Postmenopausal women | Postmenopausal women who have had a hysterectomy
Recommendation | Do not prescribe combined estrogen and progestin for the prevention of chronic conditions. Grade: D | Do not prescribe estrogen for the prevention of chronic conditions. Grade: D

Risk Assessment | This recommendation applies to the average-risk population. Risk factors for a specific chronic disease or individual characteristics that affect the likelihood of a specific therapy-associated adverse event may cause a woman's net balance of benefits and harms to differ from that of the average population.
Preventive Medications | Although combined estrogen and progestin therapy (specifically, oral conjugated equine estrogen, 0.625 mg/d, plus medroxyprogesterone acetate, 2.5 mg/d) decreases the risk for fractures in postmenopausal women, there is an accompanying increased risk for serious adverse events, such as stroke, invasive breast cancer, dementia, gallbladder disease, deep venous thrombosis, and pulmonary embolism. Estrogen therapy (specifically, oral conjugated equine estrogen, 0.625 mg/d) decreases the risk for fractures and has a small effect on the risk for invasive breast cancer, but it is also associated with important harms, such as an increased likelihood of stroke, deep venous thrombosis, and gallbladder disease. Neither combined estrogen and progestin therapy nor estrogen alone reduces the risk for coronary heart disease in postmenopausal women.
Balance of Benefits and Harms | The chronic disease prevention benefits of combined estrogen and progestin do not outweigh the harms in most postmenopausal women. | The chronic disease prevention benefits of estrogen are unlikely to outweigh the harms in most postmenopausal women who have had a hysterectomy.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for osteoporosis and the use of preventive medications for breast cancer, as well as other relevant interventions for the primary or secondary prevention of chronic diseases in women, such as medications for cardiovascular disease and screening for coronary heart disease, high blood pressure, lipid disorders, colorectal cancer, breast cancer, and dementia. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Motor Vehicle Occupant Restraints

Title | Primary Care Counseling for Proper Use of Motor Vehicle Occupant Restraints
Population | General primary care population
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Interventions | There is good evidence that community and public health interventions, including legislation, law enforcement campaigns, car seat distribution campaigns, media campaigns, and other community-based interventions, are effective in improving the proper use of car seats, booster seats, and seat belts.
Suggestions for Practice | Current evidence is insufficient to assess the incremental benefit of counseling in primary care settings, beyond increases related to other interventions, in improving rates of proper use of motor vehicle occupant restraints. Linkages between primary care and community interventions are critical for improving proper car seat, booster seat, and seat belt use.
Relevant Recommendations from the Guide to Community Preventive Services | The Community Preventive Services Task Force has reviewed evidence of the effectiveness of selected population-based interventions to reduce motor vehicle occupant injuries, focusing on three strategic areas:; - Increasing the proper use of child safety seats.; - Increasing the use of safety belts.; - Reducing alcohol-impaired driving.; Multiple interventions in these areas have been recommended. Recommendations can be accessed at http://www.thecommunityguide.org/mvoi/

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Obesity in Adults

Title | Screening for and Management Of Obesity In Adults
Population | Adults aged 18 years or older
Recommendation | Screen for obesity. Patients with a body mass index (BMI) of 30 kg/m^2^ or higher should be offered or referred to intensive, multicomponent behavioral interventions. Grade: B

Screening Tests | Body mass index is calculated from the measured weight and height of an individual. Recent evidence suggests that waist circumference may be an acceptable alternative to BMI measurement in some patient subpopulations.
Timing of Screening | No evidence was found about appropriate intervals for screening.
Interventions | Intensive, multicomponent behavioral interventions for obese adults include the following components:; - Behavioral management activities, such as setting weight-loss goals; - Improving diet or nutrition and increasing physical activity; - Addressing barriers to change; - Self-monitoring; - Strategizing how to maintain lifestyle changes
Balance of Benefits and Harms | Adequate evidence indicates that intensive, multicomponent behavioral interventions for obese adults can lead to weight loss, as well as improved glucose tolerance and other physiologic risk factors for cardiovascular disease. Inadequate evidence was found about the effectiveness of these interventions on long-term health outcomes (for example, mortality, cardiovascular disease, and hospitalizations). Adequate evidence indicates that the harms of screening and behavioral interventions for obesity are small. Possible harms of behavioral weight-loss interventions include decreased bone mineral density and increased fracture risk, serious injuries resulting from increased physical activity, and increased risk for eating disorders.
Other relevant USPSTF recommendations | Recommendations on screening for obesity in children and adolescents can be found at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Oral Cancer

Title | Screening for Oral Cancer
Population | Asymptomatic adults aged 18 years or older
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | The primary risk factors for oral cancer are tobacco and alcohol use. Additional risk factors include male sex, older age, use of betel quid, ultraviolet light exposure, infection with Candida or bacterial flora, and a compromised immune system. Recently, sexually transmitted oral human papillomavirus infection has been recognized as an increasing risk factor for oropharyngeal cancer, another subset of head and neck cancer.
Screening Tests | The primary screening test for oral cancer is a systematic clinical examination, including inspection and palpation of the oral cavity.
Treatment | Suspected oral cancer or its precursors detected on examination require confirmation by tissue biopsy. Treatment for screen-detected oral cancer includes surgery, radiotherapy, and chemotherapy.
Balance of Benefits and Harms | The USPSTF found inadequate evidence on the diagnostic accuracy, benefits, and harms of screening for oral cancer. Therefore, the USPSTF cannot determine the balance of benefits and harms of screening for oral cancer in asymptomatic adults.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on counseling to prevent tobacco use and screening for and counseling to reduce alcohol misuse. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Osteoporosis

Title | Screening for Osteoporosis
Population | Women age ≥65 years without previous known fractures or secondary causes of osteoporosis | Women age <65 years whose 10-year fracture risk is equal to or greater than that of a 65-year-old white woman without additional risk factors | Men without previous known fractures or secondary causes of osteoporosis
Recommendation | Screen for osteoporosis. Grade: B | | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | As many as 1 in 2 postmenopausal women and 1 in 5 older men are at risk for an osteoporosis-related fracture. Osteoporosis is common in all racial groups but is most common in white persons. Rates of osteoporosis increase with age. Elderly people are particularly susceptible to fractures. According to the FRAX fracture risk assessment tool, available at http://www.shef.ac.uk/FRAX/, the 10-year fracture risk in a 65-year-old white woman without additional risk factors is 9.3%.
Screening Tests | Current diagnostic and treatment criteria rely on dual-energy x-ray absorptiometry of the hip and lumbar spine.
Timing of Screening | Evidence is lacking about optimal intervals for repeated screening.
Intervention | In addition to adequate calcium and vitamin D intake and weight-bearing exercise, multiple U.S. Food and Drug Administration-approved therapies reduce fracture risk in women with low bone mineral density and no previous fractures, including bisphosphonates, parathyroid hormone, raloxifene, and estrogen. The choice of treatment should take into account the patient's clinical situation and the tradeoff between benefits and harms. Clinicians should provide education about how to minimize drug side effects.
Suggestions for Practice Regarding the I Statement for Men | Clinicians should consider:; - potential preventable burden: increasing because of the aging of the U.S. population; - potential harms: likely to be small, mostly opportunity costs; - current practice: routine screening of men not widespread; - costs: additional scanners required to screen sizeable populations; Men most likely to benefit from screening have a 10-year risk for osteoporotic fracture equal to or greater than that of a 65-year-old white woman without risk factors. However, current evidence is insufficient to assess the balance of benefits and harms of screening for osteoporosis in men.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Ovarian Cancer

Title | Screening for Ovarian Cancer
Population | Asymptomatic women without known genetic mutations that increase risk for ovarian cancer
Recommendation | Do not screen for ovarian cancer. Grade: D

Risk Assessment | Women with BRCA1 and BRCA2 genetic mutations, the Lynch syndrome (hereditary nonpolyposis colon cancer), or a family history of ovarian cancer are at increased risk for ovarian cancer. Women with an increased-risk family history should be considered for genetic counseling to further evaluate their potential risks. “Increased-risk family history” generally means having 2 or more first- or second-degree relatives with a history of ovarian cancer or a combination of breast and ovarian cancer; for women of Ashkenazi Jewish descent, it means having a first-degree relative (or 2 second-degree relatives on the same side of the family) with breast or ovarian cancer.
Screening Tests | Transvaginal ultrasonography and serum cancer antigen (CA)–125 testing are the most commonly suggested screening modalities.
Treatments | Treatment of ovarian carcinoma includes surgical treatment (debulking) and intraperitoneal or systemic chemotherapy.
Balance of Benefits and Harms | Annual screening with transvaginal ultrasonography and serum CA-125 testing in women does not decrease ovarian cancer mortality. Screening for ovarian cancer can lead to important harms, including major surgical interventions in women who do not have cancer. Therefore, the harms of screening for ovarian cancer outweigh the benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made a recommendation on genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility. This recommendation is available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Peripheral Artery Disease

Title | Screening for Peripheral Artery Disease and Cardiovascular Disease Risk Assessment with the Ankle Brachial Index in Adults
Population | Asymptomatic adults without a known diagnosis of peripheral artery disease (PAD), cardiovascular disease, severe chronic kidney disease, or diabetes
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Important risk factors for PAD include older age, diabetes, smoking, hypertension, high cholesterol level, obesity, and physical inactivity. Peripheral artery disease is more common in men than women and occurs at an earlier age in men.
Screening Tests | Resting ankle-brachial index (ABI) is the most commonly used test in screening for and detection of PAD in clinical settings. It is calculated as the systolic blood pressure obtained at the ankle divided by the systolic blood pressure obtained at the brachial artery while the patient is lying down. Physical examination has low sensitivity for detecting mild PAD in asymptomatic persons.
Balance of Benefits and Harms | Evidence on screening for PAD with the ABI in asymptomatic adults with no known diagnosis of cardiovascular disease or diabetes is insufficient; therefore, the balance of benefits and harms cannot be determined.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on using nontraditional risk factors, including the ABI, in screening for coronary heart disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Prostate Cancer

Title | Screening for Prostate Cancer
Population | Adult males
Recommendation | Do not use prostate-specific antigen (PSA)-based screening for prostate cancer. Grade: D

Screening Tests | Contemporary recommendations for prostate cancer screening all incorporate the measurement of serum PSA levels; other methods of detection, such as digital rectal examination or ultrasonography, may be included. There is convincing evidence that PSA-based screening programs result in the detection of many cases of asymptomatic prostate cancer, and that a substantial percentage of men who have asymptomatic cancer detected by PSA screening have a tumor that either will not progress or will progress so slowly that it would have remained asymptomatic for the man's lifetime (i.e., PSA-based screening results in considerable overdiagnosis).
Interventions | Management strategies for localized prostate cancer include watchful waiting, active surveillance, surgery, and radiation therapy. There is no consensus regarding optimal treatment.
Balance of Benefits and Harms | The reduction in prostate cancer mortality 10 to 14 years after PSA-based screening is, at most, very small, even for men in the optimal age range of 55 to 69 years. The harms of screening include pain, fever, bleeding, infection, and transient urinary difficulties associated with prostate biopsy, psychological harm of false-positive test results, and overdiagnosis. Harms of treatment include erectile dysfunction, urinary incontinence, bowel dysfunction, and a small risk for premature death. Because of the current inability to reliably distinguish tumors that will remain indolent from those destined to be lethal, many men are being subjected to the harms of treatment for prostate cancer that will never become symptomatic. The benefits of PSA-based screening for prostate cancer do not outweigh the harms.
Relevant USPSTF Recommendations | Recommendations on screening for other types of cancer can be found at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Sexually Transmitted Infections

Title | Behavioral Counseling to Prevent Sexually Transmitted Infections
Population | All sexually active adolescents | Adults at increased risk for STIs | Non-sexually-active adolescents and adults not at increased risk for STIs
Recommendation | Offer high-intensity counseling. Grade: B | Offer high-intensity counseling. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | All sexually active adolescents are at increased risk for STIs and should be offered counseling. Adults should be considered at increased risk and offered counseling if they have:; - Current STIs or have had an STI within the past year.; - Multiple sexual partners.; In communities or populations with high rates of STIs, all sexually active patients in non-monogamous relationships may be considered at increased risk.
Interventions | Characteristics of successful high-intensity counseling interventions:; - Multiple sessions of counseling.; - Frequently delivered in group settings.
Suggestions for Practice | High-intensity counseling may be delivered in primary care settings, or in other sectors of the health system and community settings after referral. Delivery of this service may be greatly improved by strong linkages between the primary care setting and community. | Evidence is limited regarding counseling for adolescents who are not sexually active. Intensive counseling for all adolescents in order to reach those who are at risk but have not been appropriately identified is not supported by current evidence. Evidence is lacking regarding the effectiveness of counseling for adults not at increased risk for STIs.
Other Relevant USPSTF Recommendations | USPSTF recommendations on screening for chlamydial infection, gonorrhea, genital herpes, hepatitis B, hepatitis C, HIV, and syphilis can be found at http://www.uspreventiveservicestaskforce.org.

Abbreviation: STI = Sexually Transmitted Infection

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Skin Cancer (Counseling)

Title | Behavioral Counseling to Prevent Skin Cancer
Population | Children, adolescents, and young adults aged 10 to 24 years with fair skin | Adults older than age 24 years
Recommendation | Provide counseling about minimizing exposure to ultraviolet radiation to reduce risk for skin cancer. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Individuals with a fair skin type are at greatly increased risk for skin cancer. Fair skin type can be defined by eye and hair color; freckling; and historical factors, such as usual reaction to sun exposure (always or usually burning or infrequently tanning).
Behavioral Counseling | Effective counseling interventions were generally of low intensity and almost entirely accomplished within the primary care visit. Successful counseling interventions used cancer prevention or appearance-focused messages (such as stressing the aging effect of ultraviolet radiation on the skin) to reach specific audiences.
Interventions | Behavior change interventions are aimed at reducing ultraviolet radiation exposure. Sun-protective behaviors include the use of a broad-spectrum sunscreen with a sun protection factor ≥ 15, wearing hats or other shade-protective clothing, avoiding the outdoors during midday hours (10 a.m. to 3 p.m.), and avoiding the use of indoor tanning.
Balance of Benefits and Harms | For children, adolescents, and young adults aged 10 to 24 years with fair skin, primary care counseling interventions can increase the use of sun-protective behaviors by a moderate amount, with no appreciable harms. | For adults older than 24 years, there is inadequate evidence to determine the effect of counseling on the use of sun-protective behaviors.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for skin cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Skin Cancer (Screening)

Title | Screening for Skin Cancer
Population | Adult general population 1
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Skin cancer risks: family history of skin cancer, considerable history of sun exposure and sunburn. Groups at increased risk for melanoma:; - Fair-skinned men and women over the age of 65 years.; - Patients with atypical moles.; - Patients with more than 50 moles.
Screening Tests | There is insufficient evidence to assess the balance of benefits and harms of whole body skin examination by a clinician or patient skin self-examination for the early detection of skin cancer.
Screening Intervals | Not applicable.
Suggestions for Practice | Clinicians should remain alert for skin lesions with malignant features that are noted while performing physical examinations for other purposes. Features associated with increased risk for malignancy include: asymmetry, border irregularity, color variability, diameter >6mm (“A,” “B,” “C,” “D”), or rapidly changing lesions. Suspicious lesions should be biopsied.
Other Relevant Recommendations from the USPSTF and the Community Preventive Services Task Force | The USPSTF has reviewed the evidence for counseling to prevent skin cancer. The recommendation statement and supporting documents can be accessed at http://www.uspreventiveservicestaskforce.org. The Community Preventive Services Task Force has reviewed the evidence on public health interventions to reduce skin cancer. The recommendations can be accessed at http://www.thecommunityguide.org.

1 The USPSTF does not examine outcomes related to surveillance of patients with familial syndromes, such as familial atypical mole and melanoma (FAM-M) syndrome.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Suicide Risk

Title | Screening for Suicide Risk
Population | General population
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | The strongest risk factors for attempted suicide include mood disorders or other mental disorders, comorbid substance abuse disorders, history of deliberate self-harm, and a history of suicide attempts. Deliberate self-harm refers to intentionally initiated acts of self-harm with a nonfatal outcome (including self-poisoning and self-injury). Suicide risk is assessed along a continuum ranging from suicidal ideation alone (relatively less severe) to suicidal ideation with a plan (more severe). Suicidal ideation with a specific plan of action is associated with a significant risk for attempted suicide.
Screening Tests | There is limited evidence on the accuracy of screening tools to identify suicide risk in the primary care setting, including tools to identify those at high risk. The characteristics of the most commonly used screening instruments (Scale for Suicide Ideation, Scale for Suicide Ideation-Worst, and the Suicidal Ideation Questionnaire) have not been validated to assess suicide risk in primary care settings.
Interventions | There is insufficient evidence to determine if treatment of persons at high risk for suicide reduces suicide attempts or mortality.
Balance of Benefits and Harms | There is no evidence that screening for suicide risk reduces suicide attempts or mortality. There is insufficient evidence to determine if treatment of persons at high risk reduces suicide attempts or mortality. There are no studies that directly address the harms of screening and treatment for suicide risk. As a result, the USPSTF could not determine the balance of benefits and harms of screening for suicide risk in the primary care setting.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on screening for alcohol misuse, depression, and illicit drug use. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## Syphilis (Pregnant Women)

Title | Screening for Syphilis Infection in Pregnancy
Population | All pregnant women
Recommendation | Screen for syphilis infection. Grade: A

Screening Tests | Nontreponemal tests commonly used for initial screening include:; - Venereal Disease Research Laboratory (VDRL); - Rapid Plasma Reagin (RPR); Confirmatory tests include:; - Fluorescent treponemal antibody absorbed (FTA-ABS); - Treponema pallidum particle agglutination (TPPA)
Timing of Screening | Test all pregnant women at the first prenatal visit.
Other Clinical Considerations | Most organizations recommend testing high-risk women again during the third trimester and at delivery. Groups at increased risk include:; - Uninsured women; - Women living in poverty; - Sex workers; - Illicit drug users; - Those diagnosed with other sexually transmitted infections (STIs); - Other women living in communities with high syphilis morbidity; Prevalence is higher in southern U.S. and in metropolitan areas and in Hispanic and African American populations.
Interventions | The Centers for Disease Control and Prevention (CDC) recommends treatment with parenteral benzathine penicillin G. Women with penicillin allergies should be desensitized and treated with penicillin. Consult the CDC for the most up-to-date recommendations: http://www.cdc.gov/std/treatment/.
Other Relevant USPSTF Recommendations | Recommendations on screening for other STIs, and on counseling for STIs, can be found at http://www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Testicular Cancer

Title | Screening for Testicular Cancer
Population | Adolescent and adult males
Recommendation | Do not screen. Grade: D

Screening Tests | There is inadequate evidence that screening asymptomatic patients by means of self-examination or clinician examination has greater yield or accuracy for detecting testicular cancer at more curable stages.
Interventions | Management of testicular cancer consists of orchiectomy and may include other surgery, radiation therapy, or chemotherapy, depending on stage and tumor type. Regardless of disease stage, over 90% of all newly diagnosed cases of testicular cancer will be cured.
Balance of Benefits and Harms | Screening by self-examination or clinician examination is unlikely to offer meaningful health benefits, given the very low incidence and high cure rate of even advanced testicular cancer. Potential harms include false-positive results, anxiety, and harms from diagnostic tests or procedures.
Other Relevant USPSTF Recommendations | Recommendations on screening for other types of cancer can be found at http://www.uspreventiveservicestaskforce.org.

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## Tobacco Use in Adults

Title | Counseling and Interventions to Prevent Tobacco Use and Tobacco-Caused Disease in Adults and Pregnant Women
Population | Adults age ≥ 18 years | Pregnant women of any age
Recommendation | Ask about tobacco use. Provide tobacco cessation interventions to those who use tobacco products. Grade: A | Ask about tobacco use. Provide augmented pregnancy-tailored counseling for women who smoke. Grade: A

Counseling | The “5-A” framework provides a useful counseling strategy:; 1. Ask about tobacco use.; 2. Advise to quit through clear personalized messages.; 3. Assess willingness to quit.; 4. Assist to quit.; 5. Arrange follow-up and support.; Intensity of counseling matters: brief one-time counseling works; however, longer sessions or multiple sessions are more effective. Telephone counseling “quit lines” also improve cessation rates.
Pharmacotherapy | Combination therapy with counseling and medications is more effective than either component alone. FDA-approved pharmacotherapy includes nicotine replacement therapy, sustained-release bupropion, and varenicline. | The USPSTF found inadequate evidence to evaluate the safety or efficacy of pharmacotherapy during pregnancy.
Implementation | Successful implementation strategies for primary care practice include:; - Instituting a tobacco user identification system.; - Promoting clinician intervention through education, resources, and feedback.; - Dedicating staff to provide treatment, and assessing the delivery of treatment in staff performance evaluations.
Other Relevant USPSTF Recommendations | Recommendations on other behavioral counseling topics are available at http://www.uspreventiveservicestaskforce.org.

Abbreviations: FDA = U.S. Food and Drug Administration; USPSTF = U.S. Preventive Services Task Force

For a summary of the evidence systematically reviewed in making these recommendations, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org.

## *Vitamin D and Calcium Supplementation to Prevent Fractures

Title | Vitamin D and Calcium Supplementation to Prevent Fractures in Adults
Population | Men or premenopausal women | Community-dwelling postmenopausal women at doses of >400 IU of vitamin D_3_ and >1,000 mg of calcium | Community-dwelling postmenopausal women at doses of ≤400 IU of vitamin D_3_ and ≤1,000 mg of calcium
Recommendation | No recommendation. Grade: I (Insufficient Evidence) | No recommendation. Grade: I (Insufficient Evidence) | Do not supplement. Grade: D recommendation

Preventive Medications | Appropriate intake of vitamin D and calcium are essential to overall health. However, there is inadequate evidence to determine the effect of combined vitamin D and calcium supplementation on the incidence of fractures in men or premenopausal women. There is adequate evidence that daily supplementation with 400 IU of vitamin D_3_ and 1,000 mg of calcium has no effect on the incidence of fractures in postmenopausal women. There is inadequate evidence regarding the effect of higher doses of combined vitamin D and calcium supplementation on fracture incidence in community-dwelling postmenopausal women.
Balance of Benefits and Harms | Evidence is lacking regarding the benefit of daily vitamin D and calcium supplementation for the primary prevention of fractures, and the balance of benefits and harms cannot be determined. | Evidence is lacking regarding the benefit of daily supplementation with >400 IU of vitamin D_3_ and >1,000 mg of calcium for the primary prevention of fractures in postmenopausal women, and the balance of benefits and harms cannot be determined. | Daily supplementation with ≤400 IU of vitamin D_3_ and ≤1,000 mg of calcium has no net benefit for the primary prevention of fractures.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for osteoporosis and vitamin D supplementation to prevent falls in community-dwelling older adults. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.

## *Vitamin Supplementation to Prevent Cardiovascular Disease and Cancer

Title | Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer
Population | Healthy adults without special nutritional needs. This recommendation does not apply to children, women who are pregnant or may become pregnant, or persons who are chronically ill or hospitalized or have a known nutritional deficiency.
Recommendation | Multivitamins: No recommendation. Grade: I statement | Single- or paired-nutrient supplements: No recommendation. Grade: I statement | β-carotene or vitamin E: Do not recommend. Grade: D

Preventive Medications | Evidence on supplementation with multivitamins to reduce the risk for cardiovascular disease or cancer is inadequate, as is the evidence on supplementation with individual vitamins, minerals, or functional pairs. Supplementation with β-carotene or vitamin E does not reduce the risk for cardiovascular disease or cancer.
Balance of Benefits and Harms | The evidence is insufficient to determine the balance of benefits and harms of supplementation with multivitamins for the prevention of cardiovascular disease or cancer. | The evidence is insufficient to determine the balance of benefits and harms of supplementation with single or paired nutrients for the prevention of cardiovascular disease or cancer. | There is no net benefit of supplementation with vitamin E or β-carotene for the prevention of cardiovascular disease or cancer.
Other Relevant USPSTF Recommendations | The USPSTF has made several recommendations on the prevention of cardiovascular disease and cancer, including recommendations for smoking cessation; screening for lipid disorders, hypertension, diabetes, and cancer; obesity screening and counseling; and aspirin use. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.