# Preventive Services Recommended by the USPSTF

The U.S. Preventive Services Task Force (USPSTF) recommends that clinicians discuss these preventive services with eligible patients and offer them as a priority. All these services have received an “A” or a “B” (recommended) grade from the Task Force. For definitions of all grades used by the USPSTF, see Appendix A (beginning on p. 85). Clinical summaries of recommendations for adults begin on p. 5. Clinical summaries of recommendations for children begin on p. 57.

Recommendation | Adults | | Special Populations
Recommendation | Men | Women | Pregnant Women | Children
Abdominal Aortic Aneurysm, Screening^1^ | ✓
Alcohol Misuse Screening and Behavioral Counseling Interventions | ✓ | ✓ | ✓
Aspirin for Prevention of Cardiovascular Disease^2^ | ✓ | ✓
Asymptomatic Bacteriuria in Adults, Screening^3^ | | | ✓
Breast and Ovarian Cancer Susceptibility, Genetic Risk Assessment and BRCA Mutation Testing^4^ | | ✓
Breast Cancer, Screening^5^ | | ✓
Breastfeeding, Primary Care Interventions to Promote^6^ | | ✓ | ✓
Cervical Cancer, Screening^7^ | | ✓
Chlamydial Infection, Screening^8^ | | ✓ | ✓
Colorectal Cancer, Screening^9^ | ✓ | ✓
Congenital Hypothyroidism, Screening^10^ | | | | ✓
Depression in Adults, Screening^11^ | ✓ | ✓
Diabetes Mellitus (Type 2) in Adults, Screening^12^ | ✓ | ✓
Folic Acid to Prevent Neural Tube Defects^13^ | | ✓ | ✓
Gonococcal Ophthalmia Neonatorum, Preventive Medication^14^ | | | | ✓
Gonorrhea, Screening^15^ | | ✓ | ✓
Hearing Loss in Newborns, Screening^16^ | | | | ✓
Hepatitis B Virus in Pregnant Women, Screening^17^ | | | ✓
High Blood Pressure (Adults), Screening | ✓ | ✓
HIV, Screening^18^ | ✓ | ✓ | ✓ | ✓
Iron Deficiency Anemia, Prevention^19^ | | | | ✓
Iron Deficiency Anemia, Screening^20^ | | | ✓
Lipid Disorders in Adults, Screening^21^ | ✓ | ✓
Major Depressive Disorder in Children, Screening^22^ | | | | ✓
Obesity in Children and Adolescents, Screening^23^ | | | | ✓
Osteoporosis, Screening^24^ | | ✓
Phenylketonuria, Screening^25^ | | | | ✓
Rh (D) Incompatibility, Screening^26^ | | | ✓
Sexually Transmitted Infections, Counseling^27^ | ✓ | ✓ | | ✓
Sickle Cell Disease, Screening^28^ | | | | ✓
Syphilis Infection, Screening^29^ | ✓ | ✓
Syphilis Infection in Pregnancy, Screening | | | ✓
Tobacco Use in Adults and Pregnant Women, Counseling^30^ | ✓ | ✓ | ✓
Visual Impairment in Children Ages 1 to 5, Screening^31^ | | | | ✓

1 One-time screening by ultrasonography in men aged 65 to 75 who have ever smoked.

2 When the potential harm of an increase in gastrointestinal hemorrhage is outweighed by a potential benefit of a reduction in myocardial infarctions (men aged 45–79 years) or in ischemic strokes (women aged 55–79 years).

3 Pregnant women at 12–16 weeks gestation or at first prenatal visit, if later.

4 Refer women whose family history is associated with an increased risk for deleterious mutations in BRCA1 or BRCA 2 genes for genetic counseling and evaluation for BRCA testing.

5 Biennial screening mammography for women aged 50 to 74 years. Note: The Department of Health and Human Services, in implementing the Affordable Care Act, follows the 2002 USPSTF recommendation for screening mammography, with or without clinical breast examination, every 1–2 years for women aged 40 and older.

6 Interventions during pregnancy and after birth to promote and support breastfeeding.

7 Screen with cytology every 3 years (women ages 21 to 65) or co-test (cytology/HPV testing) every 5 years (women ages 30–65).

8 Sexually active women 24 and younger and other asymptomatic women at increased risk for infection. Asymptomatic pregnant women 24 and younger and others at increased risk.

9 Adults aged 50–75 using fecal occult blood testing, sigmoidoscopy, or colonoscopy.

10 Newborns.

11 When staff-assisted depression care supports are in place to assure accurate diagnosis, effective treatment, and followup.

12 Asymptomatic adults with sustained blood pressure greater than 135/80 mg Hg.

13 All women planning or capable of pregnancy take a daily supplement containing 0.4 to 0.8 mg (400 to 800 μg) of folic acid.

14 Newborns.

15 Sexually active women, including pregnant women 25 and younger, or at increased risk for infection.

16 Newborns.

17 Screen at first prenatal visit.

18 All adolescents and adults and increased risk for HIV infection and all pregnant women.

19 Routine iron supplementation for asymptomatic children aged 6 to 12 months who are at increased risk for iron deficiency anemia.

20 Routine screening in asymptomatic pregnant women.

21 Men aged 20–35 and women over age 20 who are at increased risk for coronary heart disease; all men aged 35 and older.

22 Adolescents (age 12 to 18) when systems are in place to ensure accurate diagnosis, psychotherapy, and followup.

23 Screen children aged 6 years and older; offer or refer for intensive counseling and behavioral interventions.

24 Women aged 65 years and older and women under age 65 whose 10-year fracture risk is equal to or greater than that of a 65-year-old white woman without additional risk factors.

25 Newborns.

26 Blood typing and antibody testing at first pregnancy-related visit. Repeated antibody testing for unsensitized Rh (D)-negative women at 24–28 weeks gestation unless biological father is known to be Rh (D) negative.

27 All sexually active adolescents and adults at increased risk for STIs.

28 Newborns.

29 Persons at increased risk.

30 Ask all adults about tobacco use and provide tobacco cessation interventions for those who use tobacco; provide augmented, pregnancy-tailored counseling for those pregnant women who smoke.

31 Screen children ages 3 to 5 years.

All clinical summaries in this Guide are abridged recommendations. To see the full recommendation statements and recommendations published after March 2012, go to www.USPreventiveServicesTaskForce.org.