# Immunizations

The USPSTF recognizes the importance of immunizations in primary disease prevention. However, the USPSTF does not wish to duplicate the significant investment of resources made by others to review new evidence on immunizations in a timely fashion and make recommendations.

The Centers for Disease Control and Prevention’s (CDC’s) Advisory Committee on Immunization Practices (ACIP) publishes recommendations on immunizations for children and adults. The methods used by the ACIP to review evidence on immunizations may differ from the methods used by the USPSTF.

For the ACIP’s current recommendations on immunizations, please refer to the National Immunization Program Web site at www.cdc.gov/vaccines/recs/schedules/default.htm.