# Appendixes

Appendix A How the U.S. Preventive Services Task Force Grades Its Recommendations

Appendix B Members of the U.S. Preventive Services Task Force 2002–2012

Appendix C Acknowledgements

Appendix D About the U.S. Preventive Services Task Force

Appendix E More Resources

Appendix F Screening for Breast Cancer