# More Resources

## AHRQ’s Prevention and Chronic Care Program

AHRQ’s Prevention and Chronic Care Program Web site (www.preventiveservices.ahrq.gov) presents information that supports AHRQ’s mission to improve the quality, safety, efficiency, and effectiveness of health care for all Americans with a focus on evidence-based preventive and chronic care services. The Program’s Web site includes tools, resources, and materials to support health care organizations and engage the entire health care delivery system.

The Program includes two overall project areas with specific areas of focus:

■ Improving Primary Care Practice
  – Care coordination
  – Clinical-community linkages
  – Health care/system redesign
  – Health information technology integration
  – Behavioral and mental health
  – Self-management support
■ Evidence-Based Decisionmaking
  – Clinical decision support
  – Multiple chronic conditions

## myhealthfinder

A consumer-friendly resource, myhealthfinder (available at www.healthfinder.gov) helps people create a customized list of relevant recommendations for preventive services based on age, sex, and pregnancy status, along with explanations of each recommendation in plain language.

## Stay Healthy Brochures

Consumers can use the information in this series of brochures to learn which screening tests they need and when to get them, which medicines may prevent diseases, and daily steps to take for good health. The series includes Men Stay Healthy at Any Age, Women Stay Healthy at Any Age, Men Stay Healthy at 50+ and Women Stay Healthy at 50+, all in English and Spanish. Go to www.ahrq.gov/clinic/ppipix.htm for the list and choose the title you are interested in.

## Community Preventive Services Task Force

Established in 1996 by the U.S. Department of Health and Human Services, the Community Preventive Services Task Force (CPSTF) complements the work of the USPSTF, by addressing preventive services at the community level. The CPSTF assists agencies, organizations, and individuals at all levels (national, State, community, school, worksite, and health care system) by providing evidence-based recommendations about community prevention programs and policies that are effective in saving lives, increasing longevity, and improving Americans’ quality of life. The recommendations of the CPSTF are available at www.thecommunityguide.org.

## Healthy People 2020

Healthy People 2020 is an initiative from the U.S. Department of Health and Human Services that challenges individuals, communities, and professionals to take specific steps to ensure good health. Healthy People provides science-based, 10-year national objectives for improving the health of all Americans. Read more at www.healthypeople.gov/2020/default.aspx.

## National Guideline Clearinghouse^TM^

A public resource for evidence-based clinical practice guidelines, NGC (guideline.gov/index.aspx) was originally created by AHRQ in partnership with the American Medical Association and the American Association of Health Plans (now America’s Health Insurance Plans). The NGC mission is to provide physicians and other health professionals, health care providers, health plans, integrated delivery systems, purchasers, and others an accessible mechanism for obtaining objective, detailed information on clinical practice guidelines and to further their dissemination, implementation, and use of this information.

## Canadian Task Force on Preventive Health Care

The Task Force was established by the Public Health Agency of Canada to develop clinical practice guidelines that support primary care providers in delivering preventive health care. The mandate of the Task Force is to develop and disseminate clinical practice guidelines for primary and preventive care, based on systematic analysis of scientific evidence. Read more at www.canadiantaskforce.ca/.

## Cancer Control P.L.A.N.E.T

A service of the National Cancer Institute, the Cancer Control P.L.A.N.E.T. portal provides access to Web-based resources that can help planners, program staff, and researchers to design, implement, and evaluate evidence-based cancer control programs. Read more at cancercontrolplanet.cancer.gov/index.html.

## HealthCare.gov

This Web site (www.healthcare.gov), managed by the U.S. Department of Health and Human Services, helps people take health care into their own hands. It provides information about insurance options, using insurance, the Affordable Care Act, comparing providers, and prevention and wellness—including which preventive services are covered under the Act.