# Acknowledgements

## AHRQ Staff Supporting the USPSTF 2012

Aileen Buckler, M.D., M.P.H.

Joel Boches

Robert Cosby, Ph.D.

Jennifer Croswell, M.D., M.P.H.

Sandra K. Cummings

Farah Englert

Saeed Fatemi

Janice Genevro, Ph.D., M.S.W.

Margi Grady

Alison Hunt

William Hyde, M.L.S.

Kristie Kiser

Biff LeVee

Iris Mabry-Hernandez, M.D., M.P.H.

Corey Mackison, M.S.A.

Andrew Marshall

Robert McNellis, M.P.H., P.A.

David Meyers, M.D.

Tess Miller, Dr.P.H.

Emily Moser

Lisa Nicolella

Linwood Norman, M.S.

Janine Payne, M.P.H.

Kathryn Ramage

Richard Ricciardi, Ph.D., N.P., F.A.A.N.P.

Randie Siegel, M.S.

Gloria Washington

Rachel Weinstein

Claire Weschler, M.S.Ed.

Tracy Wolff, M.D., M.P.H.

## Evidence-Based Practice Centers Supporting the USPSTF for Recommendations in the 2012 Edition

The following researchers, working through four AHRQ Evidence-Based Practice Centers, prepared systematic evidence reviews and evidence summaries as resources on topics under consideration by the USPSTF.

### Oregon Evidence-Based Practice Center

Howard Balshem, M.S.; Tracy Beil, M.S.; Ian Blazina, M.P.H.; Christina Bougatsos, M.P.H.; Brittany Burda, M.P.H.; Amy Cantor, M.D., M.P.H.; Roger Chou, M.D.; Erika Cottrell, Ph.D., M.P.P.; Tracy Dana, M.L.S.; Mark Deffebach, M.D.; Elizabeth Eckstrom, M.D.; Michelle Eder, Ph.D.; Stephen Fortmann, M.D.; Rochelle Fu, Ph.D.; Jessica Griffin, M.A.; Jeanne-Marie Guise, M.D., M.P.H.; Andrew Hamilton, M.S., M.L.S.; Mark Helfand, M.D., M.P.H.; Linda Humphrey, M.D., M.P.H.; Tanya Kapka, M.D., M.P.H.; P. Todd Korthuis, M.D., M.P.H; Jennifer Lin, M.D.; Kevin W. Lutz, M.F.A.; Yvonne Michael, Sc.D.; Jennifer Mitchell, B.A.; Heidi D. Nelson, M.D., M.P.H.; Carrie Patnode, Ph.D., M.P.H.; Leslie Perdue, M.P.H; Daphne Plaut, M.L.S.; Elizabeth O’Connor, Ph.D.; Basmah Rahman, M.P.H.; Bruin Rugge, M.D., M.P.H.; Shelley Selph, M.D.; Caitlyn Senger, M.P.H.; Christopher Slatore, M.D., M.E.; Beth Smith, D.O.; Xin Sun, Ph.D.; Matthew Thompson, M.D., M.P.H., D.Phil.; Kimberly Vesco, M.D., M.P.H.; Miranda Walker, M.A.; Ngoc Wasson, M.P.H.; Evelyn P. Whitlock, M.D., M.P.H.; Clara Williams, M.P.A.; Bernadette Zakher, M.B.B.S.

### RTI International/University of North Carolina Evidence-Based Practice Center

Alice Ammerman, Dr.P.H., R.D.; James D. Bader, D.D.S., M.P.H.; Rainer Beck, M.D.; John F. Boggess, M.D.; Malaz Boustani, M.D., M.P.H.; Seth Brody, M.D.; Audrina J. Bunton; Katrina Donahue, M.D., M.P.H.; Louise Fernandez, P.A.-C., R.D., M.P.H.; Kenneth Fink, M.D., M.G.A., M.P.H.; Carol Ford, M.D.; Angela Fowler-Brown, M.D.; Bradley N. Gaynes, M.D., M.P.H.; Paul Godley, M.D., M.P.H.; Susan A. Hall, M.S.; Laura Hanson, M.D., M.P.H.; Russell Harris, M.D., M.P.H.; Katherine E.Hartmann, M.D., Ph.D.; Michael Hayden, M.D.; M. Brian Hemphill, M.D.; Alissa Driscoll Jacobs, M.S., R.D.; Jana Johnson; Linda Kinsinger, M.D., M.P.H.; Carol Krasnov; Ramesh Krishnaraj; Carole M. Lannon, M.D., M.P.H.; Carmen Lewis, M.D., M.P.H.; Kathleen N. Lohr, Ph.D.; Linda J. Lux, M.P.A.; Kathleen McTigue, M.D., M.P.H.; Catherine Mills, M.A.; Kavita Nanda, M.D., M.H.S.; Carla Nester, M.D.; Britt Peterson, M.D., M.P.H.; Christopher J. Phillips, M.D., M.P.H.; Michael Pignone, M.D., M.P.H.; Mark Pletcher, M.D., M.P.H.; Saif S. Rathore; Melissa Rich, M.D.; Gary Rozier, D.D.S.; Jerry L. Rushton, M.D., M.P.H.; Lucy A. Savitz; Joe Scattoloni; Stacey Sheridan, M.D., M.P.H.; Sonya Sutton, B.S.P.H.; Jeffrey A. Tice, M.D.; Suzanne L. West, Ph.D.; B. Lynn Whitener, Dr.P.H., M.S.L.S.; Margaret Wooddell, M.A.; Dennis Zolnoun, M.D.

### University of Ottawa Evidence-Based Practice Center

Nicholas Barrowman, Ph.D.; Catherine Code, M.D., F.R.C.P.C.; Catherine Dubé, M.D., M.Sc., F.R.C.P.C.; Gabriela Lewin, M.D.; David Moher, Ph.D.; Alaa Rostom, M.D., M.Sc., F.R.C.P.C.; Margaret Sampson, M.I.L.S.; Alexander Tsertsvadze, M.D., M.Sc.

### Tufts - New England Medical Center Evidence-Based Practice Center

Priscilla Chew; Mei Chung, Ph.D., M.P.H.; Deirdre DeVine; Stanley Ip, M.D.; Joseph Lau, M.D.; Gowri Raman, M.D.; Thomas Trikalinos, M.D., Ph.D.

## Liaisons to the USPSTF

Primary care partners include:

■ American Academy of Family Physicians (AAFP)
■ American Academy of Nurse Practitioners (AANP)
■ American Academy of Pediatrics (AAP)
■ American Academy of Physician Assistants (AAPA)
■ American College of Obstetricians and Gynecologists (ACOG)
■ American College of Physicians (ACP)
■ American College of Preventive Medicine (ACPM)
■ American Osteopathic Association (AOA)
■ National Association of Pediatric Nurse Practitioners (NAPNAP)

Policy, population, and quality improvement partners include:

■ America’s Health Insurance Plans (AHIP)
■ AARP
■ National Committee for Quality Assurance (NCQA)

Federal partners include:

■ Centers for Disease Control and Prevention (CDC)
■ Centers for Medicare & Medicaid Services (CMS)
■ U.S. Food and Drug Administration (FDA)
■ Health Resources and Services Administration (HRSA)
■ Indian Health Service (IHS)
■ National Institutes of Health (NIH)
■ Veteran’s Health Administration (VHA)
■ Department of Defense/Military Health System (DoD/MHS)
■ Office of Disease Prevention and Health Promotion (ODPHP)
■ Office of the Surgeon General