# Members of the U.S. Preventive Services Task Force 2002–2012

Janet D. Allan, Ph.D., R.N., C.S., F.A.A.N.

School of Nursing

University of Maryland, Baltimore

Baltimore, MD

Linda Ciofu Baumann, Ph.D., R.N.

School of Nursing and School of Medicine & Public Health

University of Wisconsin

Madison, WI

Alfred O. Berg, M.D., M.P.H.

University of Washington

Seattle, WA

Kirsten Bibbins-Domingo, Ph.D., M.D.

San Francisco General Hospital

University of California,

San Francisco, CA

Adelita Gonzales Cantu, R.N., Ph.D.

University of Texas Health Science Center

San Antonio, TX

Ned Calonge, M.D., M.P.H.

Colorado Department of Public Health and Environment

Denver, CO

Susan J. Curry, Ph.D.

College of Public Health

University of Iowa

Iowa City, IA

Thomas G. DeWitt, M.D.

Department of Pediatrics

Children’s Hospital Medical Center

Cincinnati, OH

Allen J. Dietrich, M.D.

Dartmouth Medical School

Hanover, NH

Mark Ebell, M.D., M.S.

The University of Georgia

Athens, GA

Glenn Flores, M.D.

University of Texas

Southwestern Medical Center and Children’s Medical Center of Dallas

Dallas, TX

Paul S. Frame, M.D.

Tri-County Family Medicine

Cohocton, MY

Joxel Garcia, M.D., M.B.A.

Pan American Health Organization

Washington, DC

Leon Gordis, M.D., Dr.P.H.

Johns Hopkins Bloomberg School of Public Health

Baltimore, MD

Kimberly D. Gregory, M.D., M.P.H.

Cedars-Sinai Medical Center

Los Angeles, CA

David Grossman, M.D., M.P.H.

Center for Health Studies, Group Health Cooperative

University of Washington

Seattle, WA

Russell Harris, M.D., M.P.H.

University of North Carolina School of Medicine

Chapel Hill, NC

Jessica Herzstein, M.D., M.P.H.

Air Products

Allentown, PA

Charles J. Homer, M.D., M.P.H.

National Initiative for Children’s

Healthcare Quality

Boston, MA

George Isham, M.D., M.S.

HealthPartners

Minneapolis, MN

Mark S. Johnson, M.D., M.P.H.

New Jersey Medical School

University of Medicine and Dentistry of New Jersey

Newark, NJ

Kenneth Kizer, M.D., M.P.H.

National Quality Forum

Washington, DC

Jonathan D. Klein, M.D., M.P.H.

University of Rochester

Rochester, NY

Tracy A. Lieu, M.D., M.P.H.

Harvard Pilgrim Health Care and Harvard Medical School

Boston, MA

Michael L. LeFevre, M.D., M.S.P.H.

University of Missouri School of Medicine

Columbia, MO

Rosanne Leipzig, M.D., Ph.D.

Mount Sinai School of Medicine

New York, NY

Carol Loveland-Cherry, Ph.D., R.N., F.A.A.N.

School of Nursing

University of Michigan

Ann Arbor, MI

Lucy N. Marion, Ph.D., R.N.

School of Nursing

Medical College of Georgia

Augusta, GA

Joy Melnikow, M.D., M.P.H.

University of California Davis

Sacramento, CA

Bernadette Melnyk, Ph.D., R.N., C.P.N.P./N.P.P.

College of Nursing & Healthcare Innovation

Arizona State University

Phoenix, AZ

Virginia A. Moyer, M.D., M.P.H.

University of Texas Health Science Center

Houston, TX

Cynthia D. Mulrow, M.D., M.Sc.

University of Texas Health Science Center

Audie L. Murphy Memorial Veterans Hospital

San Antonio, TX

Wanda Nicholson, M.D., M.P.H., M.B.A.

Johns Hopkins School of Medicine and Bloomberg School of Public Health

Baltimore, MD

Judith K. Ockene, Ph.D., M.Ed.

University of Massachusetts Medical School

Worcester, MA

C. Tracy Orleans, Ph.D.

The Robert Wood Johnson Foundation

Princeton, NJ

Douglas K. Owens, M.D., M.S.

VA Palo Alto Health Care System

Freeman Spogli Institute for International Studies

Stanford University

Stanford, CA

Jeffrey F. Peipert, M.D., M.P.H.

Women and Infants’ Hospital

Providence, RI

Nola J. Pender, Ph.D., R.N.

School of Nursing

University of Michigan

Ann Arbor, MI

Diana B. Petitti, M.D., M.P.H.

Fulton School of Engineering

Arizona State University

Tempe, AZ

Carolina Reyes, M.D.

University of Southern California, Los Angeles County/USC Medical Center

Los Angeles, CA

George F. Sawaya, M.D.

University of California, San Francisco

San Francisco, CA

J. Sanford (Sandy) Schwartz, M.D.

University of Pennsylvania School of Medicine and Wharton School

Philadelphia, PA

Harold C. Sox, Jr., M.D.

Dartmouth-Hitchcock Medical Center

Lebanon, NH

Albert L. Siu, M.D.

Mount Sinai Medical Center

New York, NY

Steven M. Teutsch, M.D., M.P.H.

Merck and Company, Inc.

West Point, PA

Carolyn Westhoff, M.D., M.Sc.

Columbia University

New York, NY

Timothy Wilt, M.D., M.P.H.

Minneapolis VA Medical Center

University of Minnesota

Minneapolis, MN

Steven H. Woolf, M.D., M.P.H.

Virginia Commonwealth University

Fairfax, VA

Barbara P. Yawn, M.D., M.S.P.H., M.Sc.

Olmstead Medical Center

Rochester, MN