# Recommendations for Adults

## SCREENING FOR ABDOMINAL AORTIC ANEURYSM

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Men ages 65 to 75 years who have ever smoked | Men ages 65 to 75 years who have never smoked | Women ages 65 to 75 years
Recommendation | Screen once for abdominal aortic aneurysm with ultrasonography. Grade: B | No recommendation for or against screening. Grade: C | Do not screen for abdominal aortic aneurysm. Grade: D

Risk Assessment | The major risk factors for abdominal aortic aneurysm include male sex, a history of ever smoking (defined as 100 cigarettes in a person’s lifetime), and age of 65 years or older.
Screening Tests | Screening abdominal ultrasonography is an accurate test when performed in a setting with adequate quality assurance (i.e., in an accredited facility with credentialed technologists). Abdominal palpation has poor accuracy and is not an adequate screening test.
Timing of Screening | One-time screening to detect an abdominal aortic aneurysm using ultrasonography is sufficient. There is negligible health benefit in re-screening those who have normal aortic diameter on initial screening.
Interventions | Open surgical repair of an aneurysm of at least 5.5 cm leads to decreased abdominal aortic aneurysm-related mortality in the long term; however, there are major harms associated with this procedure.
Balance of Benefits and Harms | In men ages 65 to 75 years who have ever smoked, the benefits of screening for abdominal aortic aneurysm outweigh the harms. | In men ages 65 to 75 years who have never smoked, the balance between the benefits and harms of screening for abdominal aortic aneurysm is too close to make a general recommendation for this population. | The potential overall benefit of screening for abdominal aortic aneurysm among women ages 65 to 75 years is low because of the small number of abdominal aortic aneurysm-related deaths in this population and the harms associated with surgical repair.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for carotid artery stenosis, coronary heart disease, high blood pressure, lipid disorders, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING AND BEHAVIORAL COUNSELING INTERVENTIONS IN PRIMARY CARE TO REDUCE ALCOHOL MISUSE

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adults, including pregnant women | Adolescents
Recommendation | Screen and provide behavioral counseling interventions to reduce alcohol misuse. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | “Risky” or “hazardous” drinking has been defined in the United States as more than 7 drinks per week or more than 3 drinks per occasion for women, and more than 14 drinks per week or more than 4 drinks per occasion for men. “Harmful drinking” describes persons who are currently experiencing physical, social, or psychological harm from alcohol use but do not meet criteria for dependence. Alcohol abuse and dependence are defined by specific criteria in the DSM-IV.
Screening Tests | The Alcohol Use Disorders Identification Test (AUDIT) is the most studied screening tool for detecting the full spectrum of alcohol-related problems in primary care settings. The 4-item CAGE is the most popular screening test for detecting alcohol abuse or dependence. TWEAK, a 5-item scale, and the T-ACE are designed to screen pregnant women for alcohol misuse. They detect lower levels of alcohol consumption that may pose risks during pregnancy. Clinicians may choose screening strategies that are appropriate for their clinical population and setting.
Timing of Screening | The optimal interval for screening and intervention is unknown. Patients with past alcohol problems, young adults, and other high-risk groups (e.g., smokers) may benefit most from frequent screening.
Interventions | Effective behavioral interventions to reduce risky/hazardous and harmful drinking include an initial counseling session of about 15 minutes, feedback, advice, and goal-setting. Most also include further assistance and followup. Resources that help clinicians deliver effective interventions include brief provider training or access to specially trained primary care practitioners or health educators, and the presence of office-level system supports (prompts, reminders, counseling algorithms, and patient education materials). All pregnant women and women contemplating pregnancy should be informed of the harmful effects of alcohol on the fetus. Referral or specialty treatment is recommended for individuals meeting the diagnostic criteria for alcohol dependence.
Balance of Benefits and Harms | Screening in primary care settings can accurately identify patients whose alcohol consumption does not meet criteria for alcohol dependence, but places them at risk for increased morbidity and mortality. Brief behavioral counseling interventions with followup produce small to moderate reductions in alcohol consumption that are sustained over 6 to 12 months or longer. | The evidence is insufficient to assess the potential benefits and harms of screening and behavioral counseling interventions in this population.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on screening for illicit drug use and counseling for tobacco cessation in adolescents, adults, and pregnant women. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## ASPIRIN FOR THE PREVENTION OF CARDIOVASCULAR DISEASE

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Men age 45–79 years | Women age 55–79 years | Men age <45 years | Women age <55 years | Men & Women age ≥80 years
Recommendation | Encourage aspirin use when potential CVD benefit (MIs prevented) outweighs potential harm of GI hemorrhage. | Encourage aspirin use when potential CVD benefit (strokes prevented) outweighs potential harm of GI hemorrhage. | Do not encourage aspirin use for MI prevention. | Do not encourage aspirin use for stroke prevention. | No Recommendation
| Grade: A | | Grade: D | | Grade: I (Insufficient Evidence)

How to Use This Recommendation | Shared decisionmaking is strongly encouraged with individuals whose risk is close to (either above or below) the estimates of 10-year risk levels indicated below. As the potential CVD benefit increases above harms, the recommendation to take aspirin should become stronger. To determine whether the potential benefit of MIs prevented (men) and strokes prevented (women) outweighs the potential harm of increased GI hemorrhage, both 10-year CVD risk and age must be considered. Risk level at which CVD events prevented (benefit) exceeds GI harms
How to Use This Recommendation | Men 10-year CHD risk | | Women 10-year stroke risk
How to Use This Recommendation | Age 45–59 years | ≥4% | Age 55–59 years | ≥3%
How to Use This Recommendation | Age 60–69 years | ≥9% | Age 60–69 years | ≥8%
How to Use This Recommendation | Age 70–79 years | ≥12% | Age 70–79 years | ≥11%
How to Use This Recommendation | The table above applies to adults who are not taking NSAIDs and who do not have upper GI pain or a history of GI ulcers. NSAID use and history of GI ulcers raise the risk of serious GI bleeding considerably and should be considered in determining the balance of benefits and harms. NSAID use combined with aspirin use approximately quadruples the risk of serious GI bleeding compared to the risk with aspirin use alone. The rate of serious bleeding in aspirin users is approximately 2–3 times higher in patients with a history of GI ulcers.
Risk Assessment | For men: Risk factors for CHD include age, diabetes, total cholesterol level, HDL level, blood pressure, and smoking. CHD risk estimation tool: http://hp2010.nhlbihin.net/atpiii/calculator.asp For women: Risk factors for ischemic stroke include age, high blood pressure, diabetes, smoking, history of CVD, atrial fibrillation, and left ventricular hypertrophy. Stroke risk estimation tool: http://www.westernstroke.org/index.php?header_name=stroke_tools.gif&main=stroke_tools.php
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for abdominal aortic aneurysm, carotid artery stenosis, coronary heart disease, high blood pressure, lipid disorders, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org.

Abbreviations: CHD = coronary heart disease, CVD = cardiovascular disease, GI = gastrointestinal, HDL = high-density lipoprotein, MI = myocardial infarction, NSAIDs = nonsteroidal anti-inflammatory drugs.

## ROUTINE ASPIRIN OR NONSTEROIDAL ANTI-INFLAMMATORY DRUG (NSAID) USE FOR THE PRIMARY PREVENTION OF COLORECTAL CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults at average risk for colorectal cancer
Recommendation | Do not use aspirin or NSAIDs for the prevention of colorectal cancer. Grade: D

Risk Assessment | The major risk factors for colorectal cancer are older age (older than age 50 years), family history (having two or more first-or second-degree relatives with colorectal cancer), and African American race.
Balance of Benefits and Harms | Aspirin and NSAIDs, taken in higher doses for longer periods, reduce the incidence of adenomatous polyps. However, there is poor evidence that aspirin and NSAID use leads to a reduction in colorectal cancer-associated mortality. Aspirin increases the incidence of gastrointestinal bleeding and hemorrhagic stroke; NSAIDs increase the incidence of gastrointestinal bleeding and renal impairment, especially in the elderly. The USPSTF concluded that the harms outweigh the benefits of aspirin and NSAID use for the prevention of colorectal cancer.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for colorectal cancer and aspirin use for the prevention of cardiovascular disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR BACTERIAL VAGINOSIS IN PREGNANCY TO PREVENT PRETERM DELIVERY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic pregnant women without risk factors for preterm delivery | Asymptomatic pregnant women with risk factors for preterm delivery
Recommendation | Do not screen. Grade: D | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Risk factors of preterm delivery include:; - African-American women.; - Pelvic infection.; - Previous preterm delivery.; Bacterial vaginosis is more common among African-American women, women of low socioeconomic status, and women who have previously delivered low-birth-weight infants.
Screening Tests | Bacterial vaginosis is diagnosed using Amsel’s clinical criteria or Gram stain. When using Amsel’s criteria, 3 out of 4 criteria must be met to make a clinical diagnosis:; 1. Vaginal pH >4.7.; 2. The presence of clue cells on wet mount.; 3. Thin homogeneous discharge.; 4. Amine ‘fishy odor’ when potassium hydroxide is added to the discharge.
Screening Intervals | Not applicable.
Treatment | Treatment is appropriate for pregnant women with symptomatic bacterial vaginosis infection. Oral metronidazole and oral clindamycin, as well as vaginal metronidazole gel or clindamycin cream, are used to treat bacterial vaginosis. The optimal treatment regimen is unclear.^1^

1 The Centers for Disease Control and Prevention (CDC) recommends 250 mg oral metronidazole 3 times a day for 7 days as the treatment for bacterial vaginosis in pregnancy.

## SCREENING FOR ASYMPTOMATIC BACTERIURIA IN ADULTS

CLINICAL SUMMARY OF A U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION STATEMENT

Population | All pregnant women | Men and nonpregnant women
Recommendation | Screen with urine culture. Grade: A | Do not screen. Grade: D

Detection and Screening Tests | Asymptomatic bacteriuria can be reliably detected through urine culture. The presence of at least 105 colony-forming units per mL of urine, of a single uropathogen, and in a midstream clean-catch specimen is considered a positive test result.
Screening Intervals | A clean-catch urine specimen should be collected for screening culture at 12–16 weeks’ gestation or at the first prenatal visit, if later. The optimal frequency of subsequent urine testing during pregnancy is uncertain. | Do not screen.
Benefits of Detection and Early Treatment | The detection and treatment of asymptomatic bacteriuria with antibiotics significantly reduces the incidence of symptomatic maternal urinary tract infections and low birthweight. | Screening men and nonpregnant women for asymptomatic bacteriuria is ineffective in improving clinical outcomes.
Harms of Detection and Early Treatment | Potential harms associated with treatment of asymptomatic bacteriuria include:; - Adverse effects from antibiotics.; - Development of bacterial resistance.
Other Relevant USPSTF Recommendations | Additional USPSTF recommendations involving screening for infectious conditions during pregnancy can be found at www.uspreventiveservicestaskforce.org/recommendations.htm#obstetric and www.uspreventiveservicestaskforce.org/recommendations.htm#infectious.

## SCREENING FOR BLADDER CANCER^*^ * New recommendations released March 2010 to March 2012.

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Risk factors for bladder cancer include:; - Smoking; - Occupational exposure to carcinogens (e.g., rubber, chemical, and leather industries); - Male sex; - Older age; - White race; - Infections caused by certain bladder parasites; - Family or personal history of bladder cancer
Screening Tests | Screening tests for bladder cancer include:; - Microscopic urinalysis for hematuria; - Urine cytology; - Urine biomarkers
Interventions | The principal treatment for superficial bladder cancer is transurethral resection of the bladder tumor, which may be combined with adjuvant radiation therapy, chemotherapy, biologic therapies, or photodynamic therapies. Radical cystectomy, often with adjuvant chemotherapy, is used in cases of surgically resectable invasive bladder cancer.
Balance of Benefits and Harms | There is inadequate evidence that treatment of screen-detected bladder cancer leads to improved morbidity or mortality. There is inadequate evidence on harms of screening for bladder cancer.
Suggestions for Practice | In deciding whether to screen for bladder cancer, clinicians should consider the following:; - Potential preventable burden: early detection of tumors with malignant potential could have an important impact on the mortality rate of bladder cancer.; - Potential harms: false-positive results may lead to anxiety and unneeded evaluations, diagnostic-related harms from cystoscopy and biopsy, harms from labeling and unnecessary treatments, and overdiagnosis.; - Current practice: screening tests used in primary practice include microscopic urinalysis for hematuria and urine cytology; urine biomarkers are not commonly used in part because of cost. Patients with positive findings are typically referred to a urologist for further evaluation.
Other Relevant USPSTF Recommendations | Recommendations on screening for other types of cancer can be found at www.uspreventiveservicestaskforce.org.

## GENETIC RISK ASSESSMENT AND BREAST CANCER SUSCEPTIBILITY GENE (BRCA) MUTATION TESTING FOR BREAST AND OVARIAN CANCER SUSCEPTIBILITY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Women whose family history is not associated with an increased risk for deleterious mutations in the BRCA1 or BRCA2 gene | Women whose family history is associated with an increased risk for deleterious mutations in the BRCA1 or BRCA2 gene
Recommendation | Do not refer patients for genetic counseling or BRCA testing. Grade: D | Refer patients for genetic counseling and evaluation for BRCA testing. Grade: B

Risk Assessment | An increased-risk family history is defined as follows: For non-Ashkenazi Jewish women: 2 first-degree relatives with breast cancer, 1 of whom received the diagnosis at age 50 years or younger; a combination of 3 or more first- or second-degree relatives with breast cancer, regardless of age at diagnosis; a combination of both breast and ovarian cancer among first- and second-degree relatives; a first-degree relative with bilateral breast cancer; a combination of 2 or more first- or second-degree relatives with ovarian cancer, regardless of age at diagnosis; a first- or second-degree relative with both breast and ovarian cancer at any age; or a history of breast cancer in a male relative. For women of Ashkenazi Jewish heritage: an increased-risk family history includes any first-degree relative (or 2 second-degree relatives on the same side of the family) with breast or ovarian cancer. About 2% of adult women in the general population have an increased-risk family history as defined here. There are tools available to predict the risk for clinically important BRCA mutations, but these tools have not been verified in the general population. There is no evidence concerning the level of risk for a BRCA mutation that merits referral for genetic counseling.
Screening Tests | Genetic counseling includes elements of counseling, risk assessment, pedigree analysis, and, in some cases, recommendations for testing for BRCA mutations in affected family members, the patient, or both. A BRCA test is typically ordered by a physician. When done together with genetic counseling, the test assures the linkage of testing with appropriate management decisions.
Interventions | The interventions that can be offered to a woman with a deleterious BRCA1 or BRCA2 mutation or other increased risk for hereditary breast cancer include intensive screening, chemoprevention, prophylactic mastectomy or oophorectomy, or a combination.
Balance of Benefits and Harms | Women without an increased-risk family history have a low risk for developing breast or ovarian cancer associated with BRCA1 or BRCA2 mutations. There are important adverse ethical, legal, and social consequences that can result from routine referral and testing of these women. Interventions such as prophylactic surgery, chemoprevention, or intensive screening have known harms. The potential harms of routine referral for genetic counseling or BRCA testing in these women outweigh the benefits. | Women with an increased-risk family history have an increased risk for developing breast or ovarian cancer associated with BRCA1 or BRCA2 mutations. The potential benefits of referral and discussion of testing and prophylactic treatment for these women may be substantial. The benefits of referring women with an increased-risk family history to suitably trained health care providers outweigh the harms.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on mammography screening for breast cancer, screening for ovarian cancer, and chemoprevention of breast cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR BREAST CANCER PART I: USING FILM MAMMOGRAPHY

CLINICAL SUMMARY OF 2009 U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION^1^

Population | Women aged 40–49 years | Women aged 50–74 years | Women aged ≥75 years
Recommendation | Individualize decision to begin biennial screening according to the patient’s circumstances and values. Grade: C | Screen every 2 years. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | This recommendation applies to women aged ≥40 years who are not at increased risk by virtue of a known genetic mutation or history of chest radiation. Increasing age is the most important risk factor for most women.
Screening Tests | Standardization of film mammography has led to improved quality. Refer patients to facilities certified under the Mammography Quality Standards Act (MQSA), listed at http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfMQSA/mqsa.cfm
Timing of Screening | Evidence indicates that biennial screening is optimal. A biennial schedule preserves most of the benefit of annual screening and cuts the harms nearly in half. A longer interval may reduce the benefit.
Balance of Benefits and Harms | There is convincing evidence that screening with film mammography reduces breast cancer mortality, with a greater absolute reduction for women aged 50 to 74 years than for younger women. Harms of screening include psychological harms, additional medical visits, imaging, and biopsies in women without cancer, inconvenience due to false-positive screening results, harms of unnecessary treatment, and radiation exposure. Harms seem moderate for each age group. False-positive results are a greater concern for younger women; treatment of cancer that would not become clinically apparent during a woman’s life (overdiagnosis) is an increasing problem as women age.
Rationale for No Recommendation (I Statement) | | Among women 75 years or older, evidence of benefit is lacking.
Other Relevant USPSTF Recommendations | USPSTF recommendations on screening for genetic susceptibility for breast cancer and chemoprevention of breast cancer are available at http://www.uspreventiveservicestaskforce.org.

1 The U.S. Department of Health and Human Services, in implementing the Affordable Care Act under the standard it sets out in revised Section 2713(a)(5) of the Public Health Service Act, utilizes the 2002 recommendation on breast cancer screening of the U.S. Preventive Services Task Force. For clinical summary of 2002 Recommendation, see Appendix F.

## SCREENING FOR BREAST CANCER PART II: USING METHODS OTHER THAN FILM MAMMOGRAPHY

CLINICAL SUMMARY OF 2009 U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION^1^

Population | Women aged ≥40 years
Screening Method | Digital mammography | Magnetic resonance imaging (MRI) | Clinical breast examination (CBE) | Breast self-examination (BSE) Grade: D
Recommendation | Grade: I (Insufficient Evidence) | | | Breast self-examination (BSE) Grade: D

Rationale for No Recommendation or Negative Recommendation | Evidence is lacking for benefits of digital mammography and MRI of the breast as substitutes for film mammography. | | Evidence of CBE’s additional benefit, beyond mammography, is inadequate. | Adequate evidence suggests that BSE does not reduce breast cancer mortality.
Considerations for Practice
Potential Preventable Burden | For younger women and women with dense breast tissue, overall detection is somewhat better with digital mammography. | Contrast-enhanced MRI has been shown to detect more cases of cancer in very high-risk populations than does mammography. | Indirect evidence suggests that when CBE is the only test available, it may detect a significant proportion of cancer cases.
Potential Harms | It is not certain whether overdiagnosis occurs more often with digital than with film mammography. | Contrast-enhanced MRI requires injection of contrast material. MRI yields many more false-positive results and potentially more overdiagnosis than mammography. | Harms of CBE include false-positive results, which lead to anxiety, unnecessary visits, imaging, and biopsies. | Harms of BSE include the same potential harms as for CBE and may be larger in magnitude.
Costs | Digital mammography is more expensive than film. | MRI is much more expensive than mammography. | Costs of CBE are primarily opportunity costs to clinicians. | Costs of BSE are primarily opportunity costs to clinicians.
Current Practice | Some clinical practices are now switching to digital equipment. | MRI is not currently used to screen women of average risk. | No standard approach or reporting standards are in place. | The number of clinicians who teach BSE to patients is unknown; it is likely that few clinicians teach BSE to all women.

1 The U.S. Department of Health and Human Services, in implementing the Affordable Care Act under the standard it sets out in revised Section 2713(a)(5) of the Public Health Service Act, utilizes the 2002 recommendation on breast cancer screening of the U.S. Preventive Services Task Force. For clinical summary of 2002 Recommendation, see Appendix F.

## PRIMARY CARE INTERVENTIONS TO PROMOTE BREASTFEEDING

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Pregnant women | New mothers | The mother’s partner, other family members, and friends | Infants and young children
Recommendation | Promote and support breastfeeding. Grade: B

Benefits of Breastfeeding | Mothers Less likelihood of breast and ovarian cancer | Infants Fewer ear infections, lower-respiratory-tract infections, and gastrointestinal infections | Young children Less likelihood of asthma, type 2 diabetes, and obesity
Interventions to Promote Breastfeeding | Interventions to promote and support breastfeeding have been found to increase the rates of initiation, duration, and exclusivity of breastfeeding. Consider multiple strategies, including:; - Formal breastfeeding education for mothers and families; - Direct support of mothers during breastfeeding; - Training of primary care staff about breastfeeding and techniques for breastfeeding support; - Peer support; Interventions that include both prenatal and postnatal components may be most effective at increasing breastfeeding duration. In rare circumstances, for example for mothers with HIV and infants with galactosemia, breastfeeding is not recommended. Interventions to promote breastfeeding should empower individuals to make informed choices supported by the best available evidence.
Implementation | System-level interventions with senior leadership support may be more likely to be sustained over time.

## SCREENING FOR CAROTID ARTERY STENOSIS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adult general population^1^
Recommendation | Do not screen with ultrasound or other screening tests. Grade: D

Risk Assessment | The major risk factors for carotid artery stenosis (CAS) include: older age, male gender, hypertension, smoking, hypercholesterolemia, and heart disease. However, accurate, reliable risk assessment tools are not available.
Balance of Benefits and Harms | Harms outweigh benefits. In the general population, screening with carotid duplex ultrasound would result in more false-positive results than true positive results. This would lead either to surgeries that are not indicated or to confirmatory angiography. As the result of these procedures, some people would suffer serious harms (death, stroke, and myocardial infarction) that outweigh the potential benefit surgical treatment may have in preventing stroke.
Other Relevant Recommendations from the USPSTF | Adults should be screened for hypertension, hyperlipidemia, and smoking. Clinicians should discuss aspirin chemoprevention with patients at increased risk for cardiovascular disease. These recommendations and related evidence are available at http://www.uspreventiveservicestaskforce.org.

1 This recommendation applies to adults without neurological symptoms and without a history of transient ischemic attacks (TIA) or stroke. If otherwise eligible, an individual who has a carotid area TIA should be evaluated promptly for consideration of carotid endarterectomy.

## SCREENING FOR CERVICAL CANCER^*^

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Women ages 21 to 65 | Women ages 30 to 65 | Women younger than age 21 | Women older than age 65 who have had adequate prior screening and are not high risk | Women after hysterectomy with removal of the cervix and with no history of high-grade precancer or cervical cancer | Women younger than age 30
Recommendation | Screen with cytology (Pap smear) every 3 years. Grade: A | Screen with cytology every 3 years or co-testing (cytology/HPV testing) every 5 years Grade: A | Do not screen. Grade: D | Do not screen. Grade: D | Do not screen. Grade: D | Do not screen with HPV testing (alone or with cytology) Grade: D

Risk Assessment | Human papillomavirus (HPV) infection is associated with nearly all cases of cervical cancer. Other factors that put a woman at increased risk of cervical cancer include HIV infection, a compromised immune system, in utero exposure to diethylstilbestrol, and previous treatment of a high-grade precancerous lesion or cervical cancer.
Screening Tests and Interval | Screening women ages 21 to 65 years every 3 years with cytology provides a reasonable balance between benefits and harms. Screening with cytology more often than every 3 years confers little additional benefit, with large increases in harms. HPV testing combined with cytology (co-testing) every 5 years in women ages 30 to 65 years offers a comparable balance of benefits and harms, and is therefore a reasonable alternative for women in this age group who would prefer to extend the screening interval.
Timing of Screening | Screening earlier than age 21 years, regardless of sexual history, leads to more harms than benefits. Clinicians and patients should base the decision to end screening on whether the patient meets the criteria for adequate prior testing and appropriate follow-up, per established guidelines.
Interventions | Screening aims to identify high-grade precancerous cervical lesions to prevent development of cervical cancer and early-stage asymptomatic invasive cervical cancer. High-grade lesions may be treated with ablative and excisional therapies, including cryotherapy, laser ablation, loop excision, and cold knife conization. Early-stage cervical cancer may be treated with surgery (hysterectomy) or chemoradiation.
Balance of Benefits and Harms | The benefits of screening with cytology every 3 years substantially outweigh the harms. | The benefits of screening with co-testing (cytology/HPV testing) every 5 years outweigh the harms. | The harms of screening earlier than age 21 years outweigh the benefits. | The benefits of screening after age 65 years do not outweigh the potential harms. | The harms of screening after hysterectomy outweigh the benefits. | The potential harms of screening with HPV testing (alone or with cytology) outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for breast cancer and ovarian cancer, as well as genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR CHLAMYDIAL INFECTION

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Non-pregnant women | | | Pregnant women | | | Men
Population | 24 years and younger | 25 years and older | | 24 years and younger | 25 years and older | | Men
Population | Includes adolescents | Not at increased risk | At increased risk | Includes adolescents | Not at increased risk | At increased risk | Men
Recommendation | Screen if sexually active. Grade: A | Do not automatically screen. Grade: C | Screen. Grade: A | Screen. Grade: B | Do not automatically screen. Grade: C | Screen. Grade: B | No recommendation. Grade: I (Insufficient Evidence^1^)

Risk Assessment | Age: Women and men aged 24 years and younger are at greatest risk. History of: previous Chlamydial infection or other sexually transmitted infections, new or multiple sexual partners, inconsistent condom use, sex work. Demographics: African-Americans and Hispanic women and men have higher prevalence rates than the general population in many communities.
Screening Tests | Nucleic acid amplification tests (NAATs) can identify chlamydial infection in asymptomatic women (non-pregnant and pregnant) and asymptomatic men. NAATs have high specificity and sensitivity and can be used with urine and vaginal swabs.
Screening Intervals | Non-Pregnant Women The optimal interval for screening is not known. The CDC recommends that women at increased risk be screened at least annually.^2^ | Pregnant Women For women 24 years and younger and older women at increased risk: Screen at the first prenatal visit. For patients at continuing risk, or who are newly at risk: Screen in the 3rd trimester. | Not applicable
Treatment | The Centers for Disease Control and Prevention has outlined appropriate treatment at: http://www.cdc.gov/STD/treatment. Test and/or treat partners of patients treated for Chlamydial infection.

1 Chlamydial infection results in few sequelae in men. Therefore, the major benefit of screening men would be to reduce the likelihood that infected and untreated men would pass the infection to sexual partners. There is no evidence that screening men reduces the long-term consequences of chlamydial infection in women. Because of this lack of evidence, the USPSTF was not able to assess the balance of benefits and harms, and concluded that the evidence is insufficient to recommend for or against routinely screening men.

2 Centers for Disease Control and Prevention, Sexually transmitted diseases treatment guidelines, 2006. MMWR 2006. 55(No. RR-11).

## SCREENING FOR CHRONIC OBSTRUCTIVE PULMONARY DISEASE USING SPIROMETRY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adult general population
Recommendation | Do not screen for chronic obstructive pulmonary disease using spirometry. Grade: D

Additional Population Information | This screening recommendation applies to healthy adults who do not recognize or report respiratory symptoms to a clinician. It does not apply to individuals with a family history of alpha-1 antitrypsin deficiency.
Risk Assessment | Risk factors for COPD include:; - Current or past tobacco use.; - Exposure to occupational and environmental pollutants.; - Age 40 or older.
Screening Tests^1^ | Spirometry can be performed in a primary care physician’s office or a pulmonary testing laboratory. The USPSTF did not review evidence comparing the accuracy of spirometry performed in primary care versus referral settings. For individuals who present to clinicians complaining of chronic cough, increased sputum production, wheezing, or dyspnea, spirometry would be indicated as a diagnostic test for COPD, asthma, and other pulmonary diseases.
Other Approaches to the Prevention of Pulmonary Illnesses | These services should be offered to patients regardless of COPD status:; - All current smokers should receive smoking cessation counseling and be offered pharmacologic therapies demonstrated to increase cessation rates.; - All patients 50 years of age or older should be offered influenza immunization annually.; - All patients 65 years of age or older should be offered one-time pneumococcal immunization.
Other Relevant USPSTF Recommendations | Clinicians should screen all adults for tobacco use and provide tobacco cessation interventions for those who use tobacco products. The USPSTF tobacco cessation counseling recommendation and supporting evidence are available at http://www.uspreventiveservicestaskforce.org/uspstf/uspstbac.htm.

1 The potential benefit of spirometry-based screening for COPD is prevention of one or more exacerbations by treating patients found to have an airflow obstruction previously undetected. However, even in groups with the greatest prevalence of airflow obstruction, hundreds of patients would need to be screened with spirometry to defer one exacerbation.

## SCREENING FOR COLORECTAL CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adults age 50 to 75^1^ years | Adults age 76 to 85 years^1^ | Adults older than 85 years^1^
Recommendation | Screen with high sensitivity fecal occult blood testing (FOBT), sigmoidoscopy, or colonoscopy. Grade: A | Do not automatically screen. Grade: C | Do not screen. Grade: D
| For all populations, evidence is insufficient to assess the benefits and harms of screening with computerized tomography colonography (CTC) and fecal DNA testing. Grade: I (Insufficient Evidence)

Screening Tests | High sensitivity FOBT, sigmoidoscopy with FOBT, and colonoscopy are effective in decreasing colorectal cancer mortality. The risks and benefits of these screening methods vary. Colonoscopy and flexible sigmoidoscopy (to a lesser degree) entail possible serious complications.
Screening Test Intervals | Intervals for recommended screening strategies:; - Annual screening with high-sensitivity fecal occult blood testing; - Sigmoidoscopy every 5 years, with high-sensitivity fecal occult blood testing every 3 years; - Screening colonoscopy every 10 years
Balance of Benefits and Harms | The benefits of screening outweigh the potential harms for 50- to 75-year-olds. | The likelihood that detection and early intervention will yield a mortality benefit declines after age 75 because of the long average time between adenoma development and cancer diagnosis.
Implementation | Focus on strategies that maximize the number of individuals who get screened. Practice shared decisionmaking; discussions with patients should incorporate information on test quality and availability. Individuals with a personal history of cancer or adenomatous polyps are followed by a surveillance regimen, and screening guidelines are not applicable.
Other Relevant USPSTF Recommendations | The USPSTF recommends against the use of aspirin or nonsteroidal anti-inflammatory drugs for the primary prevention of colorectal cancer. This recommendation is available at http://www.uspreventiveservicestaskforce.org.

1 These recommendations do not apply to individuals with specific inherited syndromes (Lynch Syndrome or Familial Adenomatous Polyposis) or those with inflammatory bowel disease.

## USING NONTRADITIONAL RISK FACTORS IN CORONARY HEART DISEASE RISK ASSESSMENT

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic men and women with no history of coronary heart disease (CHD), diabetes, or any CHD risk equivalent
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | This recommendation applies to adult men and women classified at intermediate 10-year risk for CHD (10% to 20%) by traditional risk factors.
Importance | Coronary heart disease (CHD) is the most common cause of death in adults in the United States. Treatment to prevent CHD events by modifying risk factors is currently based on the Framingham risk model. If the classification of individuals at intermediate risk could be improved by using additional risk factors, treatment to prevent CHD might be targeted more effectively. Risk factors not currently part of the Framingham model (nontraditional risk factors) include high sensitivity C-reactive protein (hs-CRP), ankle-brachial index (ABI), leukocyte count, fasting blood glucose level, periodontal disease, carotid intima-media thickness, electron beam computed tomography, homocysteine level, and lipoprotein(a) level.
Balacne of Benefits and Harms | There is insufficient evidence to determine the percentage of intermediate-risk individuals who would be reclassified by screening with nontraditional risk factors, other than hs-CRP and ABI. For individuals reclassified as high-risk on the basis of hs-CRP or ABI scores, data are not available to determine whether they benefit from additional treatments. Little evidence is available to determine the harms of using nontraditional risk factors in screening. Potential harms include lifelong use of medications without proven benefit and psychological and other harms from being misclassified in a higher risk category.
Suggestions for practice | Clinicians should continue to use the Framingham model to assess CHD risk and guide risk-based preventive therapy. Adding nontraditional risk factors to CHD assessment would require additional patient and clinical staff time and effort. Routinely screening with nontraditional risk factors could result in lost opportunities to provide other important health services of proven benefit.
Other Relevant USPSTF Recommendations | USPSTF recommendations on risk assessment for CHD, the use of aspirin to prevent cardiovascular disease, and screening for high blood pressure can be accessed at http://www.uspreventiveservicestaskforce.org.

## SCREENING FOR DEPRESSION IN ADULTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Nonpregnant adults 18 years or older
Recommendation | Screen when staff-assisted depression care supports^1^ are in place to assure accurate diagnosis, effective treatment, and followup. Grade: B | Do not automatically screen when staff-assisted depression care supports^1^ are not in place. Grade: C

Risk Assessment | Persons at increased risk for depression are considered at risk throughout their lifetime. Groups at increased risk include persons with other psychiatric disorders, including substance misuse; persons with a family history of depression; persons with chronic medical diseases; and persons who are unemployed or of lower socioeconomic status. Also, women are at increased risk compared with men. However, the presence of risk factors alone cannot distinguish depressed patients from nondepressed patients.
Screening Tests | Simple screening questions may perform as well as more complex instruments. Any positive screening test result should trigger a full diagnostic interview using standard diagnostic criteria.
Timing of Screening | The optimal interval for screening is unknown. In older adults, significant depressive symptoms are associated with common life events, including medical illness, cognitive decline, bereavement, and institutional placement in residential or inpatient settings.
Balance of Benefits and Harms | | Limited evidence suggests that screening for depression in the absence of staff-assisted depression care does not improve depression outcomes.
Suggestions for Practice | “Staff-assisted depression care supports” refers to clinical staff that assists the primary care clinician by providing some direct depression care and/or coordination, case management, or mental health treatment.
Relevant USPSTF Recommendations | Related USPSTF recommendations on screening for suicidality and screening children and adolescents for depression are available at http://www.uspreventiveservicestaskforce.org.

1 Go to the Suggestions for Practice section of this figure for further explanation.

## SCREENING FOR TYPE 2 DIABETES MELLITUS IN ADULTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults with sustained blood pressure greater than 135/80 mm Hg | Asymptomatic adults with sustained blood pressure 135/80 mm Hg or lower
Recommendation | Screen for type 2 diabetes mellitus. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | These recommendations apply to adults with no symptoms of type 2 diabetes mellitus or evidence of possible complications of diabetes. Blood pressure measurement is an important predictor of cardiovascular complications in people with type 2 diabetes mellitus. The first step in applying this recommendation should be measurement of blood pressure (BP). Adults with treated or untreated BP >135/80 mm Hg should be screened for diabetes.
Screening Tests | Three tests have been used to screen for diabetes:; - Fasting plasma glucose (FPG).; - 2-hour postload plasma.; - Hemoglobin A1c.; The American Diabetes Association (ADA) recommends screening with FPG, defines diabetes as FPG ≥ 126 mg/dL, and recommends confirmation with a repeated screening test on a separate day.
Screening Intervals | The optimal screening interval is not known. The ADA, on the basis of expert opinion, recommends an interval of every 3 years.
Suggestions for practice regarding insufficient evidence | When BP is ≤ 135/80 mm Hg, screening may be considered on an individual basis when knowledge of diabetes status would help inform decisions about coronary heart disease (CHD) preventive strategies, including consideration of lipid-lowering agents or aspirin. To determine whether screening would be helpful on an individual basis, information about 10-year CHD risk must be considered. For example, if CHD risk without diabetes was 17% and risk with diabetes was >20%, screening for diabetes would be helpful because diabetes status would determine lipid treatment. In contrast, if risk without diabetes was 10% and risk with diabetes was 15%, screening would not affect the decision to use lipid-lowering treatment.
Other relevant information from the USPSTF and the Community Preventive Services Task Force | Evidence and USPSTF recommendations regarding blood pressure, diet, physical activity, and obesity are available at http://www.uspreventiveservicestaskforce.org. The reviews and recommendations of the Community Preventive Services Task Force may be found at http://www.thecommunityguide.org.

## FOLIC ACID FOR THE PREVENTION OF NEURAL TUBE DEFECTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Women planning a pregnancy or capable of becoming pregnant
Recommendation | Take a daily vitamin supplement containing 0.4 to 0.8 mg (400 to 800 μg) of folic acid. Grade: A

Risk Assessment | Risk factors include:; - A personal or family history of a pregnancy affected by a neural tube defect; - The use of certain antiseizure medications; - Mutations in folate-related enzymes; - Maternal diabetes; - Maternal obesity; Note: This recommendation does not apply to women who have had a previous pregnancy affected by neural tube defects or women taking certain antiseizure medicines. These women may be advised to take higher doses of folic acid.
Timing of Medication | Start supplementation at least 1 month before conception. Continue through first 2 to 3 months of pregnancy.
Recommendations of Others | ACOG, AAFP, and most other organizations recommend 4 mg/d for women with a history of a pregnancy affected by a neural tube defect.

Abbreviations: AAFP = American Academy of Family Physicians; ACOG = American College of Obstetricians and Gynecologists.

## SCREENING FOR GENITAL HERPES

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic pregnant women | Asymptomatic adolescents and adults
Recommendation | Do not screen for herpes simplex virus. Grade: D | Do not screen for herpes simplex virus. Grade: D

Screening Tests | Methods for detecting herpes simplex virus include viral culture, polymerase chain reaction, and antibody-based tests, such as the western blot assay and type-specific glycoprotein G serological tests.
Interventions | There is limited evidence that the use of antiviral therapy in women with a history of recurrent infection, or performance of cesarean delivery in women with active herpes lesions at the time of delivery, decreases neonatal herpes infection. There is also limited evidence of the safety of antiviral therapy in pregnant women and neonates. | Antiviral therapy improves health outcomes in symptomatic persons (e.g., those with multiple recurrences); however, there is no evidence that the use of antiviral therapy improves health outcomes in those with asymptomatic infection. There are multiple efficacious regimens that may be used to prevent the recurrence of clinical genital herpes.
Balance of Benefits and Harms | The potential harms of screening asymptomatic pregnant women include false-positive test results, labeling, and anxiety, as well as false-negative tests and false reassurance, although these potential harms are not well studied. The USPSTF determined that there are no benefits associated with screening, and therefore the potential harms outweigh the benefits. | The potential harms of screening asymptomatic adolescents and adults include false-positive test results, labeling, and anxiety, although these potential harms are not well studied. The USPSTF determined the benefits of screening are minimal, at best, and the potential harms outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for chlamydia, gonorrhea, HIV, and several other sexually transmitted infections. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR GESTATIONAL DIABETES MELLITUS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Pregnant women who have not previously been diagnosed with diabetes
Recommendation | No recommendation. Grade: I (Insufficient Evidence^1^).

Risk Assessment | Women at increased risk of developing gestational diabetes mellitus (GDM) include those who:; - Are obese.; - Are older than 25 years.; - Have a family history of diabetes.; - Have a history of GDM.; - Are of certain ethnic groups (Hispanic, American Indian, Asian, or African-American).
Balacne of Benefits and Harms | The current evidence is insufficient to assess the balance between the benefits and harms of screening women for GDM either before or after 24 weeks gestation. Harms of screening include short-term anxiety in some women with positive screening results, and inconvenience to many women and medical practices because most positive screening tests are likely false-positives.
Suggestions for Practice | Until there is better evidence, clinicians should discuss screening for GDM with their patients and make case-by-case decisions. The discussion should include information about the uncertain benefits and harms as well as the frequency and uncertain meaning of a positive screening test result.
Screening Tests | If a decision is made to screen for GDM: The screening test most commonly used in the United States is an initial 50-gram 1-hour glucose challenge test (GCT). If the result on the GCT is abnormal, the patient undergoes a 100-gram 3-hour oral glucose tolerance test (OGTT). Two or more abnormal values on the OGTT are considered a diagnosis of GDM.
Screening Intervals | Most screening is conducted between 24 and 28 weeks gestation. There is little evidence about the value of earlier screening.
Other Approaches to Prevention | Nearly all pregnant women should be encouraged to:; - Achieve moderate weight gain based on their pre-pregnancy body mass index.; - Participate in physical activity.

1 The current evidence is insufficient to establish the balance of benefits and harms for screening for gestational diabetes mellitus, either before or after 24 weeks gestation.

## SCREENING FOR GLAUCOMA

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | The primary risk factor for developing primary open-angle glaucoma (POAG) is increased intraocular pressure. Other important risk factors are family history, older age, and being of African American descent. Additional risk factors may include decreased central cornea thickness, low diastolic perfusion pressure, diabetes, and severe myopia.
Screening Tests | The diagnosis of POAG is not made on the basis of a single test, but on the finding of characteristic degenerative changes in the optic disc, along with a loss of visual field sensitivity. Perimetry assesses visual field loss by mapping a patient’s response to visual stimuli presented in various locations within the visual field. Perimetry may be performed by manual or automated methods. Several consistent perimetry measurements are needed to establish the presence of defects. Dilated opthalmoscopy or slit lamp examinations are used by specialists to examine changes in the optic disc; however, there is wide variability in its reliability for detecting glaucomatous optic disc progression.
Interventions | The primary treatments for POAG reduce intraocular pressure; these include medications, laser therapy, or surgery. These treatments can effectively reduce the development and progression of small visual field defects. However, their effectiveness in reducing impairment in vision-related function is uncertain. Harms caused by these interventions include formation of cataracts, harms resulting from cataract surgery, and harms of topical medication.
Balance of Benefits and Harms | Because of the uncertainty of the magnitude of benefit from early treatment and given the known harms of screening and early treatment, the USPSTF could not determine the balance between the benefits and harms of screening for glaucoma.
Other Relevant USPSTF Recommendations | The USPSTF has also made a recommendation on screening for impaired visual acuity in older adults. This recommendation is available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR GONORRHEA

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Sexually active women, including those who are pregnant, who are at increased risk for infection | Men who are at increased risk for infection | Men and women who are at low risk for infection | Pregnant women who are not at increased risk for infection
Recommendation | Screen for gonorrhea. Grade: B | No recommendation. Grade: I (Insufficient Evidence) | Do not screen for gonorrhea. Grade: D | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Women and men younger than age 25 years—including sexually active adolescents—are at highest risk for gonorrhea infection. Risk factors for gonorrhea include a history of previous gonorrhea infection, other sexually transmitted infections, new or multiple sexual partners, inconsistent condom use, sex work, and drug use. Risk factors for pregnant women are the same as for non-pregnant women.
Screening Tests | Vaginal culture is an accurate screening test when transport conditions are suitable. Newer screening tests, including nucleic acid amplification and hybridization tests, have demonstrated improved sensitivity and comparable specificity when compared with cervical culture. Some newer tests can be used with urine and vaginal swabs, which enables screening when a pelvic examination is not performed.
Timing of Screening | Screening is recommended at the first prenatal visit for pregnant women who are in a high-risk group for gonorrhea infection. For pregnant women who are at continued risk, and for those who acquire a new risk factor, a second screening should be conducted during the third trimester. The optimal interval for screening in the non-pregnant population is not known.
Interventions | Genital gonorrhea infection in men and women, including pregnant women, may be treated with a third-generation cephalosporin. Because of increased prevalence of resistant organisms, fluoroquinolones should not be used to treat gonorrhea. Current guidelines for treating gonorrhea infection are available from the Centers for Disease Control and Prevention (http://www.cdc.gov/std/treatment).
Balance of Benefits and Harms | The USPSTF concluded that the benefits of screening women at increased risk for gonorrhea infection outweigh the potential harms. | The USPSTF could not determine the balance of benefits and harms of screening for gonorrhea in men at increased risk for infection. | Given the low prevalence of gonorrhea infection in the general population, the USPSTF concluded that the potential harms of screening in low-prevalence populations outweigh the benefits. | The USPSTF could not determine the balance between the benefits and harms of screening for gonorrhea in pregnant women who are not at increased risk for infection.
Other Relevant USPSTF Recommendations | The USPSTF has also made a recommendation on ocular prophylaxis in newborns for gonococcal ophthalmia neonatorum. This recommendation is available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR HEMOCHROMATOSIS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic general population
Recommendation | Do not screen for hereditary hemochromatosis. Grade: D

Risk Assessment | Clinically recognized hereditary hemochromatosis is primarily associated with mutations on the hemochromatosis (HFE) gene. Although this is a relatively common mutation in the U.S. population, only a small subset will develop symptoms of hemochromatosis. An even smaller proportion of these individuals will develop advanced stages of clinical disease.
Screening Tests | Genetic screening for HFE mutations can accurately identify individuals at risk for hereditary hemochromatosis. However, identifying an individual with the genotypic predisposition does not accurately predict the future risk for disease manifestation.
Interventions | Therapeutic phlebotomy is the main treatment for hereditary hemochromatosis. Phlebotomy is generally thought to have few side effects.
Balance of Benefits and Harms | - Screening could lead to identification of a large number of individuals who possess the high-risk genotype but may never manifest the clinical disease. This may result in unnecessary surveillance and diagnostic procedures, labeling, anxiety, and, potentially, unnecessary treatments.; - There is poor evidence that early therapeutic phlebotomy improves morbidity and mortality in individuals with screening-detected versus clinically-detected hemochromatosis.; - The USPSTF concluded that the potential harms of genetic screening for hereditary hemochromatosis outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on genetic testing for mutations in the breast cancer susceptibility gene to predict breast and ovarian cancer susceptibility. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR HEPATITIS B VIRUS INFECTION

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | General asymptomatic population
Recommendation | Do not screen for hepatitis B virus (HBV) infection. Grade: D

Risk Assessment | The main risk factors for HBV infection include diagnosis with a sexually transmitted disease, intravenous drug use, sexual contact with multiple partners, male homosexual activity, and household contact with chronically infected persons. However, screening strategies to identify individuals at high risk have poor predictive value, since 30–40 percent of infected individuals do not have any easily identifiable risk factors.
Screening Tests | Routine screening of the general population for HBV infection is not recommended.
Interventions | Routine hepatitis vaccination has had significant impact in reducing the number of new HBV infections per year, with the greatest decline among children and adolescents. Programs that vaccinate health care workers also reduce the transmission of HBV infection.
Balance of Benefits and Harms | The USPSTF found no evidence that screening the general population for HBV infection improves long-term health outcomes such as cirrhosis, hepatocellular carcinoma, or mortality. The prevalence of HBV infection is low; the majority of infected individuals do not develop chronic infection, cirrhosis, or HBV-related liver disease. Potential harms of screening include labeling, although there is limited evidence to determine the magnitude of this harm. As a result, the USPSTF concluded that the potential harms of screening for HBV infection in the general population are likely to exceed any potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for hepatitis B infection in pregnant women and screening for hepatitis C virus infection. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR HEPATITIS B VIRUS INFECTION IN PREGNANCY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | All pregnant women
Recommendation | Screen for hepatitis B virus (HBV) at the first prenatal visit. Grade: A

Screening Tests | Serologic identification of hepatitis B surface antigen (HBsAg). Reported sensitivity and specificity are greater than 98%.
Timing of Screening | Order HBsAg testing at the first prenatal visit. Re-screen women with unknown HBsAg status or new or continuing risk factors at admission to hospital, birth center, or other delivery setting.
Interventions | Administer hepatitis B vaccine and hepatitis B immune globulin to HBV-exposed infants within 12 hours of birth. Refer women who test positive for counseling and medical management. Counseling should include information about how to prevent transmission to sexual partners and household contacts. Reassure patients that breastfeeding is safe for infants who receive appropriate prophylaxis.
Implementation | Establish systems for timely transfer of maternal HBsAg test results to the labor and delivery and newborn medical records.
Other Relevant USPSTF Recommendations | USPSTF recommendations on the screening of pregnant women for other infections, including asymptomatic bacteriuria, bacterial vaginosis, chlamydia, HIV, and syphilis, can be found at http://www.uspreventiveservicestaskforce.org.

## SCREENING FOR HEPATITIS C VIRUS IN ADULTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults who are not at increased risk for infection | Adults who are at high risk for infection
Recommendation | Do not screen for hepatitis C virus (HCV) infection. Grade: D | No recommendation. Grade: I Statement (Insufficient Evidence)

Risk Assessment | Established risk factors for HCV infection include current or past intravenous drug use, receiving a blood transfusion before 1990, dialysis, and being a child of an HCV-infected mother. Surrogate markers, such as high-risk sexual behavior (particularly sex with someone infected with HCV) and the use of illegal drugs, such as cocaine or marijuana, have also been associated with increased risk for HCV infection.
Screening Tests | Initial testing for HCV infection is typically done by enzyme immunoassay.
Interventions | Although there is good evidence that antiviral therapy improves intermediate outcomes, such as viremia, there is limited evidence that such treatment improves long-term health outcomes. The current treatment regimen is long and costly and is associated with a high patient dropout rate due to adverse effects. As of 2004, there was insufficient evidence that newer treatment regimens for HCV infection, such as pegylated interferon plus ribavirin, improve long-term health outcomes.
Balance of Benefits and Harms | The prevalence of HCV infection in the general population is low, and most who are infected do not develop cirrhosis or other major negative health outcomes. There is no evidence that screening for HCV infection leads to improved long-term health outcomes, such as decreased cirrhosis, hepatocellular cancer, or mortality. Potential harms of screening include unnecessary biopsies and labeling, although there is limited evidence to determine the magnitude of these harms. As a result, the USPSTF concluded that the potential harms of screening for HCV infection in adults who are not at increased risk for HCV infection are likely to exceed the potential benefits. | The USPSTF found no evidence that screening for HCV infection in adults at high risk leads to improved long-term health outcomes. The proportion of persons infected with HCV who progress to liver disease is uncertain. Potential harms of screening and treatment include labeling, adverse treatment effects, and unnecessary biopsies, although there is limited evidence to determine the magnitude of these harms. As a result, the USPSTF could not determine the balance of benefits and harms of screening for HCV infection in adults at increased risk for infection.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for hepatitis B virus infection in the general population and in pregnant women. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR HIGH BLOOD PRESSURE IN ADULTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adult general population^1^
Recommendation | Screen for high blood pressure. Grade: A

Screening Tests | High blood pressure (hypertension) is usually defined in adults as: systolic blood pressure (SBP) of 140 mm Hg or higher, or diastolic blood pressure (DBP) of 90 mm Hg or higher. Due to variability in individual blood pressure measurements, it is recommended that hypertension be diagnosed only after 2 or more elevated readings are obtained on at least 2 visits over a period of 1 to several weeks.
Screening Intervals | The optimal interval for screening adults for hypertension is not known. The Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC 7) recommends:; - Screening every 2 years with BP <120/80.; - Screening every year with SBP of 120–139 mmHg or DBP of 80–90 mmHg.
Treatment | A variety of pharmacological agents are available to treat hypertension. JNC 7 guidelines for treatment of hypertension can be accessed at http://www.nhlbi.nih.gov/guidelines/hypertension/jncintro.htm. The following non-pharmacological therapies are associated with reductions in blood pressure:; - Reduction of dietary sodium intake.; - Potassium supplementation.; - Increased physical activity, weight loss.; - Stress management.; - Reduction of alcohol intake.
Other Relevant USPSTF Recommendations | Adults with hypertension should be screened for diabetes. Adults should be screened for hyperlipidemia (depending on age, sex, risk factors) and smoking. Clinicians should discuss aspirin chemoprevention with patients at increased risk for cardiovascular disease. These recommendations and related evidence are available at http://www.uspreventiveservicestaskforce.org.

1 This recommendation applies to adults without known hypertension.

## SCREENING FOR HIV

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adolescents and adults at increased risk for HIV infection | Adolescents and adults who are not at increased risk for HIV infection | Pregnant women
Recommendation | Screen for HIV. Grade: A | No recommendation for or against screening. Grade: C | Screen for HIV. Grade: A

Risk Assessment | A person is considered at increased risk for HIV infection if he/she reports one or more individual risk factors or receives health care in a high-prevalence or high-risk clinical setting. High-risk settings include sexually transmitted infection (STI) clinics, correctional facilities, homeless shelters, tuberculosis clinics, clinics serving men who have sex with men, and adolescent health clinics with a high prevalence of STIs. High-prevalence settings are defined as those known to have a 1% or greater prevalence of infection among the patient population being served. Individual risk for HIV infection is assessed through a careful patient history. Individuals at increased risk include:; - Men who have had sex with men after 1975; - Persons having unprotected sex with multiple partners; - Persons who are past or present injection drug users; - Persons who exchange sex for money or drugs or have sex partners who do; - Persons whose past or present sex partners are HIV-infected, bisexual, or injection drug users; - Persons being treated for sexually transmitted diseases; - Persons with a history of blood transfusion between 1978 and 1985; - Persons who request an HIV test despite reporting no risk factors (since this group is likely to include individuals not willing to disclose high risk behaviors)
Screening Tests | The standard test for diagnosing HIV infection is the repeatedly reactive enzyme immunoassay, followed by confirmatory western blot or immunofluorescent assay. Rapid HIV antibody testing is also highly accurate, can be performed in 10 to 30 minutes, and when offered at the point of care, is useful for screening high-risk patients who do not receive regular medical care (e.g., those seen in emergency departments), as well as women with unknown HIV status who present in active labor.
Interventions | Evidence supports the benefit of identifying and treating asymptomatic individuals in immunologically advanced stages of HIV disease (i.e., CD4 cell counts <200 cells/mm^3^) with highly active antiretroviral therapy (HAART). Appropriate prophylaxis and immunization against certain opportunistic infections have also been shown to be effective interventions for these individuals. Use of HAART can be considered for asymptomatic individuals who are in an earlier stage of disease but at high risk for disease progression (i.e., CD4 cell count <350 cells/mm^3^ or viral load >100,000 copies/mL. Recommended regimens of HAART are acceptable to pregnant women and lead to significantly reduced rates of mother-to-child transmission. Early detection of maternal HIV infection also allows for discussion of elective cesarean section and avoidance of breastfeeding, both of which are associated with lower HIV transmission rates.
Balance of Benefits and Harms | The USPSTF found good evidence that screening accurately detects HIV infection and that appropriately timed interventions, particularly HAART, lead to improved health outcomes for many of those screened. False-positive test results are rare, and most adverse events associated with treatment, including metabolic disturbances with an increased risk for cardiovascular events, may be ameliorated by changes in regimen. The USPSTF concluded that the benefits of screening individuals at increased risk substantially outweigh potential harms. | The USPSTF found fair evidence that screening individuals who are not known to be at increased risk for HIV can detect additional individuals with HIV, and good evidence that appropriately timed interventions lead to improved health outcomes for some of these individuals. However, the yield of screening persons without risk factors would be low, and there are potential harms of screening. The USPSTF concluded that the benefit of screening individuals without risk factors for HIV is too small relative to the potential harms to justify a general recommendation. | The USPSTF found good evidence that screening accurately detects HIV infection in pregnant women, and fair evidence that prenatal counseling and voluntary testing increases the proportion of HIV-infected women who are diagnosed and treated before delivery. There is no evidence of fetal anomalies or other clinically important fetal harm associated with currently recommended antiretroviral regimens (except for efavirenz). Serious or fatal maternal events are rare using currently recommended combination therapies. The USPSTF concluded that the benefits of screening all pregnant women substantially outweigh the potential harms.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening and counseling for other sexually transmitted infections. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## HORMONE REPLACEMENT THERAPY FOR THE PREVENTION OF CHRONIC CONDITIONS IN POSTMENOPAUSAL WOMEN

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Postmenopausal women | Postmenopausal women who have had a hysterectomy
Recommendation | Do not use combined estrogen and progestin for the prevention of chronic conditions. Grade: D | Do not use unopposed estrogen for the prevention of chronic conditions. Grade: D

Risk Assessment | The probability that a menopausal woman will develop various chronic diseases during her lifetime is estimated to be:; - 46% for coronary heart disease; - 20% for stroke; - 15% for hip fracture; - 10% for breast cancer; - 2.6% for endometrial cancer
Preventive Medication | - Combined estrogen-progestin reduces the risk for fractures and may possibly decrease colorectal cancer risk, but it has no beneficial effect on coronary heart disease.; - Combined estrogen-progestin increases the risk for stroke, breast cancer, dementia and lower global cognitive function, venous thromboembolism, and cholecystitis.; - There is not enough evidence to determine the effects of hormone therapy on the incidence of ovarian cancer, mortality from breast cancer or coronary heart disease, or all-cause mortality.; - Evidence about the effects of different dosages, types, and delivery modes of hormone therapy remains insufficient. | - Estrogen alone decreases a woman’s risk for fractures, but it has no beneficial effect on coronary heart disease.; - Estrogen alone increases the risk for stroke, dementia and lower global cognitive function, and thromboembolism.; - The evidence is insufficient to determine the effects of unopposed estrogen on the incidence of breast cancer, ovarian cancer, or colorectal cancer, as well as breast cancer mortality or all-cause mortality.
Balance of Benefits and Harms | Overall, the harmful effects of combined estrogen and progestin are likely to exceed the benefits of chronic disease prevention for most women. | Overall, the harmful effects of unopposed estrogen are likely to exceed the chronic disease prevention benefits in most women.
Clinical Considerations | The balance of benefits and harms for a woman will be influenced by her personal preferences, her risks for specific chronic diseases, and the presence of menopausal symptoms. A shared decisionmaking approach to preventing chronic diseases in perimenopausal and postmenopausal women involves consideration of individual risk factors and preferences in selecting effective interventions for reducing the risks for fracture, heart disease, and cancer.
Other Relevant USPSTF Recommendations | Other USPSTF recommendations for prevention of chronic diseases (screening for osteoporosis, high blood pressure, lipid disorders, breast cancer, and colorectal cancer and counseling to prevent tobacco use) are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR ILLICIT DRUG USE

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adolescents, adults, and pregnant women not previously identified as users of illicit drugs
Recommendation | No recommendation. Grade I: (Insufficient Evidence)

Screening Tests | Toxicologic tests of blood or urine can provide objective evidence of drug use, but do not distinguish occasional users from impaired drug users. Valid and reliable standardized questionnaires are available to screen adolescents and adults for drug use or misuse. There is insufficient evidence to evaluate the clinical utility of these instruments when widely applied in primary care settings.
Balance of Benefits and Harms | The USPSTF concludes that for adolescents, adults, and pregnant women, the evidence is insufficient to determine the benefits and harms of screening for illicit drug use.
Suggestions for Practice | Clinicians should be alert to the signs and symptoms of illicit drug use in patients.
Treatment | More evidence is needed on the effectiveness of primary care office-based treatments for illicit drug use/dependence.
Other Relevant USPSTF Recommendations | The USPSTF recommendation for screening and counseling interventions to reduce alcohol misuse by adults and pregnant women can be found at http://www.uspreventiveservicestaskforce.org/uspstf/uspsdrin.htm.

## SCREENING FOR IMPAIRED VISUAL ACUITY IN OLDER ADULTS^1^ 1 This recommendation does not cover screening for glaucoma.

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE

Population | Adults age 65 and older
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Older age is an important risk factor for most types of visual impairment. Additional risk factors include:; - Smoking, alcohol use, exposure to ultraviolet light, diabetes, corticosteroids, and black race (for cataracts).; - Smoking, family history, and white race (for age-related macular degeneration).
Screening Tests | Visual acuity testing (for example, the Snellen eye chart) is the usual method for screening for impairment of visual acuity in the primary care setting. Screening questions are not as accurate as a visual acuity test.
Balance of Benefits and Harms | There is no direct evidence that screening for vision impairment in older adults in primary care settings is associated with improved clinical outcomes. There is evidence that early treatment of refractive error, cataracts, and age-related macular degeneration may lead to harms that are small. The magnitude of net benefit for screening cannot be calculated because of a lack of evidence.
Other Relevant USPSTF Recommendations | Recommendations on screening for glaucoma and on screening for hearing loss in older adults can be accessed at http://www.uspreventiveservicestaskforce.org.

## SCREENING FOR LIPID DISORDERS IN ADULTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | - Men age 35 years and older; - Women age 45 years and older who are at increased risk for coronary heart disease (CHD) | - Men ages 20 to 35 years who are at increased risk for CHD; - Women ages 20 to 45 years who are at increased risk for CHD | - Men ages 20 to 35 years; - Women age 20 years and older who are not at increased risk for CHD
Recommendation | Screen for lipid disorders. Grade: A | Screen for lipid disorders. Grade: B | No recommendation for or against screening Grade: C

Risk Assessment | Consideration of lipid levels along with other risk factors allows for an accurate estimation of CHD risk. Risk factors for CHD include diabetes, history of previous CHD or atherosclerosis, family history of cardiovascular disease, tobacco use, hypertension, and obesity (body mass index ≥30 kg/m^2^).
Screening Tests | The preferred screening tests for dyslipidemia are measuring serum lipid (total cholesterol, high-density and low-denisty lipoprotein cholesterol) levels in non-fasting or fasting samples. Abnormal screening results should be confirmed by a repeated sample on a separate occasion, and the average of both results should be used for risk assessment.
Timing of Screening | The optimal interval for screening is uncertain. Reasonable options include every 5 years, shorter intervals for people who have lipid levels close to those warranting therapy, and longer intervals for those not at increased risk who have had repeatedly normal lipid levels. An age at which to stop screening has not been established. Screening may be appropriate in older people who have never been screened; repeated screening is less important in older people because lipid levels are less likely to increase after age 65 years.
Interventions | Drug therapy is usually more effective than diet alone in improving lipid profiles, but choice of treatment should consider overall risk, costs of treatment, and patient preferences. Guidelines for treating lipid disorders are available from the National Cholesterol Education Program of the National Institutes of Health (http://www.nhlbi.nih.gov/about/ncep/).
Balance of Benefits and Harms | The benefits of screening for and treating lipid disorders in men age 35 and older and women age 45 and older at increased risk for CHD substantially outweigh the potential harms. | The benefits of screening for and treating lipid disorders in young adults at increased risk for CHD moderately outweigh the potential harms. | The net benefits of screening for lipid disorders in young adults not at increased risk for CHD are not sufficient to make a general recommendation.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for lipid disorders in children and screening for carotid artery stenosis, coronary heart disease, high blood pressure, and peripheral arterial disease. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR LUNG CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic persons
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Cigarette smoking is the major risk factor for lung cancer. Other risk factors include family history, chronic obstructive pulmonary disease, idiopathic pulmonary fibrosis, environmental radon exposure, passive smoking, asbestos exposure, and certain occupational exposures.
Screening Tests | Screening with low dose computerized tomography, chest x-ray, or sputum cytology can detect lung cancer at earlier stages; however, as of 2004, there is insufficient evidence that any screening strategy for lung cancer decreases mortality.
Balance of Benefits and Harms | As of 2004, the benefit of screening for lung cancer has not been established in any group, including asymptomatic high-risk populations such as older smokers. The balance of Benefits and Harms becomes increasingly unfavorable for persons at lower risk, such as nonsmokers. Because of the invasive nature of diagnostic testing and the possibility of a high number of false-positive results in certain populations, there is potential for significant harms from screening. Therefore, the USPSTF could not determine the balance between the benefits and harms of screening for lung cancer.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for many other types of cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## PRIMARY CARE COUNSELING FOR PROPER USE OF MOTOR VEHICLE OCCUPANT RESTRAINTS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATIONS

Population | General primary care population
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Interventions | There is good evidence that community and public health interventions, including legislation, law enforcement campaigns, car seat distribution campaigns, media campaigns, and other community-based interventions, are effective in improving the proper use of car seats, booster seats, and seat belts.
Suggestions for Practice | Current evidence is insufficient to assess the incremental benefit of counseling in primary care settings, beyond increases related to other interventions, in improving rates of proper use of motor vehicle occupant restraints. Linkages between primary care and community interventions are critical for improving proper car seat, booster seat, and seat belt use.
Relevant Recommendations from the Guide to Community Preventive Services | The Community Preventive Services Task Force has reviewed evidence of the effectiveness of selected population-based interventions to reduce motor vehicle occupant injuries, focusing on three strategic areas:; - Increasing the proper use of child safety seats.; - Increasing the use of safety belts.; - Reducing alcohol-impaired driving.; Multiple interventions in these areas have been recommended. Recommendations can be accessed at http://www.thecommunityguide.org/mvoi/

## SCREENING FOR ORAL CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | No recommendation. Grade: I Statement (Insufficient Evidence)

Risk Assessment | Tobacco use in all forms is the biggest risk factor for oral cancer. Alcohol abuse combined with tobacco use increases risk. Clinicians should be alert to the possibility of oral cancer when treating patients who use tobacco or alcohol.
Screening Tests | Direct inspection and palpation of the oral cavity is the most commonly recommended method of screening for oral cancer, although there are little data on the sensitivity and specificity of this method. Screening techniques other than inspection and palpation are being evaluated but are still experimental.
Interventions | Patients should be encouraged to not use tobacco and to limit alcohol use in order to decrease their risk for oral cancer, as well as for heart disease, stroke, lung cancer, and cirrhosis.
Balance of Benefits and Harms | There is no good-quality evidence that screening for oral cancer leads to improved health outcomes for either high-risk adults (i.e., adults older than age 50 years who use tobacco) or average-risk adults in the general population. It is unlikely that controlled trials of screening for oral cancer will ever be conducted in the general population because of the very low incidence of oral cancer in the United States. There is also no evidence of the harms of screening. As a result, the USPSTF could not determine the balance between the benefits and harms of screening for oral cancer.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for many other types of cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR OSTEOPOROSIS^*^

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Women age ≥65 years without previous known fractures or secondary causes of osteoporosis | Women age <65 years whose 10-year fracture risk is equal to or greater than that of a 65-year-old white woman without additional risk factors | Men without previous known fractures or secondary causes of osteoporosis
Recommendation | Screen for osteoporosis. Grade: B | | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | As many as 1 in 2 postmenopausal women and 1 in 5 older men are at risk for an osteoporosis-related fracture. Osteoporosis is common in all racial groups but is most common in white persons. Rates of osteoporosis increase with age. Elderly people are particularly susceptible to fractures. According to the FRAX fracture risk assessment tool, available at http://www.shef.ac.uk/FRAX/, the 10-year fracture risk in a 65-year-old white woman without additional risk factors is 9.3%.
Screening Tests | Current diagnostic and treatment criteria rely on dual-energy x-ray absorptiometry of the hip and lumbar spine.
Timing of Screening | Evidence is lacking about optimal intervals for repeated screening.
Intervention | In addition to adequate calcium and vitamin D intake and weight-bearing exercise, multiple U.S. Food and Drug Administration–approved therapies reduce fracture risk in women with low bone mineral density and no previous fractures, including bisphosphonates, parathyroid hormone, raloxifene, and estrogen. The choice of treatment should take into account the patient’s clinical situation and the tradeoff between benefits and harms. Clinicians should provide education about how to minimize drug side effects.
Suggestions for Practice Regarding the I Statement for Men | Clinicians should consider:; - potential preventable burden: increasing because of the aging of the U.S. population; - potential harms: likely to be small, mostly opportunity costs; - current practice: routine screening of men not widespread; - costs: additional scanners required to screen sizeable populations; Men most likely to benefit from screening have a 10-year risk for osteoporotic fracture equal to or greater than that of a 65-year-old white woman without risk factors. However, current evidence is insufficient to assess the balance of benefits and harms of screening for osteoporosis in men.

## SCREENING FOR OVARIAN CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adult women
Recommendation | Do not screen for ovarian cancer. Grade: D

Risk Assessment | The following risk factors are associated with ovarian cancer: family history, carrying the BRCA1 or BRCA2 gene mutations, and possibly taking estrogen supplementation for postmenopausal chronic conditions.
Screening Tests | Screening with serum CA-125 level or transvaginal ultrasonography may detect ovarian cancer at earlier stages than in the absence of screening; however, earlier detection likely has a small effect, at best, on mortality from ovarian cancer. Also, because there is a low incidence of ovarian cancer in the general population, screening for ovarian cancer is likely to have a relatively low yield.
Balance of Benefits and Harms | Because of the low prevalence of ovarian cancer and the invasive nature of diagnostic testing after a positive screening test, there is fair evidence that screening could likely lead to important harms. Therefore, the potential harms of screening for ovarian cancer outweigh the potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on genetic risk assessment and BRCA mutation testing for ovarian and breast cancer susceptibility, as well as screening for breast cancer and cervical cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/..

## SCREENING FOR PANCREATIC CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | Do not screen for pancreatic cancer. Grade: D

Risk Assessment | Persons with hereditary pancreatitis may have a higher lifetime risk for developing pancreatic cancer. However, the USPSTF did not review the effectiveness of screening these patients.
Balance of Benefits and Harms | The USPSTF found no evidence that screening for pancreatic cancer is effective in reducing mortality. There is a potential for significant harm due to the very low prevalence of pancreatic cancer, limited accuracy of available screening tests, the invasive nature of diagnostic tests, and the poor outcomes of treatment. As a result, the USPSTF concluded that the harms of screening for pancreatic cancer exceed any potential benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for many types of cancer. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR PERIPHERAL ARTERIAL DISEASE

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | Do not screen for peripheral arterial disease (PAD). Grade: D

Risk Assessment | Risk factors associated with PAD include older age, cigarette smoking, diabetes mellitus, hypercholesterolemia, hypertension, and possibly genetic factors.
Screening Tests | Ankle brachial index (ABI) is a simple and accurate noninvasive test for the screening and diagnosis of PAD. The ABI has demonstrated better accuracy than other methods of screening, including history taking, questionnaires, and palpation of peripheral pulses. An ABI value of less than 0.90 (95% sensitive and specific for angiographic PAD) is strongly associated with limitations in lower extremity functioning and physical activity tolerance.
Interventions | Smoking cessation and physical activity training also increase maximal walking distance among men with early PAD.
Balance of Benefits and Harms | Screening for PAD in asymptomatic adults in the general population has few or no benefits, because the prevalence of PAD in this group is low and because there is little evidence that treatment of PAD at this asymptomatic stage of disease, beyond treatment based on standard cardiovascular risk assessment, improves health outcomes. Screening asymptomatic adults with the ankle brachial index could lead to some small degree of harm, including false-positive results and unnecessary workups. Therefore, the harms of routine screening for PAD exceed the benefits for asymptomatic adults.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on screening for carotid artery stenosis, coronary heart disease, high blood pressure, and lipid disorders. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR Rh (D) INCOMPATIBILITY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Pregnant women presenting at the first visit for prenatal care | Unsensitized Rh (D)-negative women at 24–28 weeks’ gestation
Recommendation | Perform Rh (D) blood typing and antibody testing. Grade: A | Repeat Rh (D) blood typing and antibody testing. Grade: B

Screening Tests | Rh (D) blood typing and antibody testing prevents maternal sensitization and improves outcomes for newborns.
Timing of Screening | Repeated antibody testing in unsensitized Rh (D)-negative women, unless the father is also known to be Rh (D)-negative, provides additional benefit over a single test at the first prenatal visit.
Interventions | - Administration of a full (300 μg) dose of Rh (D) immunoglobulin is recommended for all unsensitized Rh (D)-negative women after repeated antibody testing at 24–28 weeks’ gestation.; - If an Rh (D)-positive or weakly Rh (D)-positive infant is delivered, a dose of Rh (D) immunoglobulin should be repeated postpartum, preferably within 72 hours after delivery.; - Unless the biological father is known to be Rh (D)-negative, a full dose of Rh (D) immunoglobulin is recommended for all unsensitized Rh (D)-negative women after amniocentesis and after induced or spontaneous abortion; however, if the pregnancy is less than 13 weeks, a 50 μg dose is sufficient.
Balance of Benefits and Harms | The benefits of Rh (D) blood typing and antibody testing at the first prenatal visit substantially outweigh any potential harms. | The benefits of repeated testing substantially outweigh any potential harms.
Other Relevant USPSTF Recommendations | The USPSTF has made recommendations on many types of obstetric screenings. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## BEHAVIORAL COUNSELING TO PREVENT SEXUALLY TRANSMITTED INFECTIONS

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | All sexually active adolescents | Adults at increased risk for STIs | Non-sexually-active adolescents and adults not at increased risk for STIs
Recommendation | Offer high-intensity counseling. Grade: B | Offer high-intensity counseling. Grade: B | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | All sexually active adolescents are at increased risk for STIs and should be offered counseling. Adults should be considered at increased risk and offered counseling if they have:; - Current STIs or have had an STI within the past year.; - Multiple sexual partners.; In communities or populations with high rates of STIs, all sexually active patients in non-monogamous relationships may be considered at increased risk.
Interventions | Characteristics of successful high-intensity counseling interventions:; - Multiple sessions of counseling.; - Frequently delivered in group settings.
Suggestions for Practice | High-intensity counseling may be delivered in primary care settings, or in other sectors of the health system and community settings after referral. Delivery of this service may be greatly improved by strong linkages between the primary care setting and community. | Evidence is limited regarding counseling for adolescents who are not sexually active. Intensive counseling for all adolescents in order to reach those who are at risk but have not been appropriately identified is not supported by current evidence. Evidence is lacking regarding the effectiveness of counseling for adults not at increased risk for STIs.
Other Relevant USPSTF Recommendations | USPSTF recommendations on screening for chlamydial infection, gonorrhea, genital herpes, hepatitis B, hepatitis C, HIV, and syphilis can be found at http://www.uspreventiveservicestaskforce.org.

Abbreviation: STI = Sexually Transmitted Infection

## SCREENING FOR SKIN CANCER

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adult general population^1^
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | Skin cancer risks: family history of skin cancer, considerable history of sun exposure and sunburn. Groups at increased risk for melanoma:; - Fair-skinned men and women over the age of 65 years.; - Patients with atypical moles.; - Patients with more than 50 moles.
Screening Tests | There is insufficient evidence to assess the balance of benefits and harms of whole body skin examination by a clinician or patient skin self-examination for the early detection of skin cancer.
Screening Intervals | Not applicable.
Suggestions for Practice | Clinicians should remain alert for skin lesions with malignant features that are noted while performing physical examinations for other purposes. Features associated with increased risk for malignancy include: asymmetry, border irregularity, color variability, diameter >6mm (“A,” “B,” “C,” “D”), or rapidly changing lesions. Suspicious lesions should be biopsied.
Other Relevant Recommendations from the USPSTF and the Community Preventive Services Task Force | The USPSTF has reviewed the evidence for counseling to prevent skin cancer. The recommendation statement and supporting documents can be accessed at http://www.uspreventiveservicestaskforce.org. The Community Preventive Services Task Force has reviewed the evidence on public health interventions to reduce skin cancer. The recommendations can be accessed at http://www.thecommunityguide.org.

1 The USPSTF does not examine outcomes related to surveillance of patients with familial syndromes, such as familial atypical mole and melanoma (FAM-M) syndrome.

## SCREENING FOR SUICIDE RISK

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | General population
Recommendation | No recommendation. Grade: I (Insufficient Evidence)

Risk Assessment | The strongest risk factors for attempted suicide include mood disorders or other mental disorders, comorbid substance abuse disorders, history of deliberate self-harm, and a history of suicide attempts. Deliberate self-harm refers to intentionally initiated acts of self-harm with a nonfatal outcome (including self-poisoning and self-injury). Suicide risk is assessed along a continuum ranging from suicidal ideation alone (relatively less severe) to suicidal ideation with a plan (more severe). Suicidal ideation with a specific plan of action is associated with a significant risk for attempted suicide.
Screening Tests | There is limited evidence on the accuracy of screening tools to identify suicide risk in the primary care setting, including tools to identify those at high risk. The characteristics of the most commonly used screening instruments (Scale for Suicide Ideation, Scale for Suicide Ideation–Worst, and the Suicidal Ideation Questionnaire) have not been validated to assess suicide risk in primary care settings.
Interventions | There is insufficient evidence to determine if treatment of persons at high risk for suicide reduces suicide attempts or mortality.
Balance of Benefits and Harms | There is no evidence that screening for suicide risk reduces suicide attempts or mortality. There is insufficient evidence to determine if treatment of persons at high risk reduces suicide attempts or mortality. There are no studies that directly address the harms of screening and treatment for suicide risk. As a result, the USPSTF could not determine the balance of benefits and harms of screening for suicide risk in the primary care setting.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on screening for alcohol misuse, depression, and illicit drug use. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR SYPHILIS INFECTION

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Persons at increased risk for syphilis infection | Asymptomatic persons who are not at increased risk for syphilis infection
Recommendation | Screen for syphilis infection. Grade: A | Do not screen for syphilis infection. Grade: D

Risk Assessment | Populations at increased risk for syphilis infection include men who have sex with men and engage in high-risk sexual behavior, commercial sex workers, persons who exchange sex for drugs, and those in adult correctional facilities. Persons diagnosed with other sexually transmitted diseases may be more likely than others to engage in high-risk behavior, placing them at increased risk.
Screening Tests | Screening for syphilis infection is a two-step process that involves an initial nontreponemal test (Venereal Disease Research Laboratory or Rapid Plasma Reagin), followed by a confirmatory treponemal test (fluorescent treponemal antibody absorbed or T. pallidum particle agglutination).
Timing of Screening | The optimal screening interval in average- and high-risk persons has not been determined.
Interventions | Preferred treatment consists of antibiotic therapy with parenterally administered penicillin G.
Balance of Benefits and Harms | Screening may result in potential harms (such as false-positive results, unnecessary anxiety to the patient, and harms of antibiotic use). However, the benefits of screening persons at increased risk for syphilis infection substantially outweigh the potential harms. | Given the low incidence of infection in the general population and the consequent low yield of such screening, the potential harms of screening (i.e., opportunity costs, false-positive tests, and labeling) in a low-incident population outweigh the benefits.
Other Relevant USPSTF Recommendations | The USPSTF has made other recommendations on screening for sexually transmitted infections, including screening for syphilis infection in pregnant women. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## SCREENING FOR SYPHILIS INFECTION IN PREGNANCY

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | All pregnant women
Recommendation | Screen for syphilis infection. Grade: A

Screening Tests | Nontreponemal tests commonly used for initial screening include:; - Venereal Disease Research Laboratory (VDRL); - Rapid Plasma Reagin (RPR); Confirmatory tests include:; - Fluorescent treponemal antibody absorbed (FTA-ABS); - Treponema pallidum particle agglutination (TPPA)
Timing of Screening | Test all pregnant women at the first prenatal visit.
Other Clinical Considerations | Most organizations recommend testing high-risk women again during the third trimester and at delivery. Groups at increased risk include:; - Uninsured women; - Women living in poverty; - Sex workers; - Illicit drug users; - Those diagnosed with other sexually transmitted infections (STIs); - Other women living in communities with high syphilis morbidity; Prevalence is higher in southern U.S. and in metropolitan areas and in Hispanic and African American populations.
Interventions | The Centers for Disease Control and Prevention (CDC) recommends treatment with parenteral benzathine penicillin G. Women with penicillin allergies should be desensitized and treated with penicillin. Consult the CDC for the most up-to-date recommendations: http://www.cdc.gov/std/treatment/.
Other Relevant USPSTF Recommendations | Recommendations on screening for other STIs, and on counseling for STIs, can be found at http://www.uspreventiveservicestaskforce.org.

## SCREENING FOR TESTICULAR CANCER^*^

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adolescent and adult males
Recommendation | Do not screen. Grade: D

Screening Tests | There is inadequate evidence that screening asymptomatic patients by means of self-examination or clinician examination has greater yield or accuracy for detecting testicular cancer at more curable stages.
Interventions | Management of testicular cancer consists of orchiectomy and may include other surgery, radiation therapy, or chemotherapy, depending on stage and tumor type. Regardless of disease stage, over 90% of all newly diagnosed cases of testicular cancer will be cured.
Balance of Benefits and Harms | Screening by self-examination or clinician examination is unlikely to offer meaningful health benefits, given the very low incidence and high cure rate of even advanced testicular cancer. Potential harms include false-positive results, anxiety, and harms from diagnostic tests or procedures.
Other Relevant USPSTF Recommendations | Recommendations on screening for other types of cancer can be found at http://www.uspreventiveservicestaskforce.org.

## SCREENING FOR THYROID DISEASE

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Asymptomatic adults
Recommendation | No recommendation. Grade: I Statement (Insufficient Evidence)

Risk Assessment | People at higher risk for thyroid dysfunction include the elderly, postpartum women, persons with high levels of radiation exposure (>20 mGy), and patients with Down syndrome.
Screening Tests | Screening for thyroid dysfunction can be performed using the medical history, physical examination, or any of several serum thyroid function tests. Thyroid stimulating hormone (TSH) is usually recommended because it can detect abnormalities before other tests become abnormal.
Interventions | A potential benefit of treating subclinical thyroid disease is to prevent the spontaneous development of overt hypothyroidism or hyperthyroidism, but this potential benefit has not been well studied in clinical trials as of 2004.
Balance of Benefits and Harms | There is fair evidence that the TSH test can detect subclinical thyroid disease in persons without symptoms of thyroid dysfunction, but poor evidence that treatment improves clinically important outcomes in adults with screen-detected thyroid disease. There is the potential for harm caused by false-positive screening tests; however, the magnitude of harm is not known. There is good evidence that overtreatment with levothyroxine occurs in a substantial proportion of patients, but the long-term harmful effects of overtreatment are not known. As a result, the USPSTF could not determine the balance of benefits and harms of screening asymptomatic adults for thyroid disease.
Other Relevant USPSTF Recommendations | The USPSTF has also made recommendations on screening for diabetes, hemochromatosis, iron deficiency anemia, and obesity. These recommendations are available at http://www.uspreventiveservicestaskforce.org/.

## COUNSELING AND INTERVENTIONS TO PREVENT TOBACCO USE AND TOBACCO-CAUSED DISEASE IN ADULTS AND PREGNANT WOMEN

CLINICAL SUMMARY OF U.S. PREVENTIVE SERVICES TASK FORCE RECOMMENDATION

Population | Adults age ≥ 18 years | Pregnant women of any age
Recommendation | Ask about tobacco use. Provide tobacco cessation interventions to those who use tobacco products. Grade: A | Ask about tobacco use. Provide augmented pregnancy-tailored counseling for women who smoke. Grade: A

Counseling | The “5-A” framework provides a useful counseling strategy:; 1. Ask about tobacco use.; 2. Advise to quit through clear personalized messages.; 3. Assess willingness to quit.; 4. Assist to quit.; 5. Arrange follow-up and support.; Intensity of counseling matters: brief one-time counseling works; however, longer sessions or multiple sessions are more effective. Telephone counseling “quit lines” also improve cessation rates.
Pharmacotherapy | Combination therapy with counseling and medications is more effective than either component alone. FDA-approved pharmacotherapy includes nicotine replacement therapy, sustained-release bupropion, and varenicline. | The USPSTF found inadequate evidence to evaluate the safety or efficacy of pharmacotherapy during pregnancy.
Implementation | Successful implementation strategies for primary care practice include:; - Instituting a tobacco user identification system.; - Promoting clinician intervention through education, resources, and feedback.; - Dedicating staff to provide treatment, and assessing the delivery of treatment in staff performance evaluations.
Other Relevant USPSTF Recommendations | Recommendations on other behavioral counseling topics are available at http://www.uspreventiveservicestaskforce.org.

Abbreviations: FDA = U.S. Food and Drug Administration; USPSTF = U.S. Preventive Services Task Force

All clinical summaries in this Guide are abridged recommendations. To see the full recommendation statements and recommendations published after March 2012, go to www.USPreventiveServicesTaskForce.org.

For a summary of the evidence systematically reviewed in making this recommendation, the full recommendation statement, and supporting documents, please go to http://www.uspreventiveservicestaskforce.org/.