# Preface

Since being codified by Congress in 1984, the U.S. Preventive Services Task Force (USPSTF) has been fulfilling its charge to conduct rigorous reviews of research evidence to create evidence-based recommendations for preventive services that should be provided in the primary care setting.

Over this quarter century of work, the USPSTF has made and maintained more than 67 separate recommendations covering services that are intended to improve health outcomes from heart disease, cancer, infectious diseases, and other conditions and events that impact the health of children, adolescents, adults, and pregnant women. The Guide to Clinical Preventive Services 2010-2011 is a compilation of abridged USPSTF recommendations, both new and updated, released from 2002 to 2010 and can be used as an evidence-based tool at the point of patient care. Recommendations that were being updated while this edition of the Guide was being compiled, as well as the complete USPSTF recommendation statements, are available along with their supporting scientific evidence at http://www.USPreventiveServicesTaskForce.org.

The use of these recommendations has evolved over time. The suggestion that it is not beneficial to provide all of the services available for prevention was nearly a heretical concept in U.S. medical practice when the first USPSTF started its work. Over time, individual health care providers, professional organizations, integrated health systems, health plans and insurers, and public programs, including the Centers for Medicare & Medicaid Services as well as groups crafting health quality measures and national health objectives, have adopted the recommendations. The primary audience for the USPSTF's work remains primary care clinicians, and the recommendations are now considered by many to provide definitive standards for preventive services.

Another exciting development is that the work of the USPSTF is central to the preventive benefits covered under the Patient Protection and Affordable Care Act. Under the new law, preventive services with a Task Force grade of A or B will be covered under new health insurance plans or policies. Even prior to national reform activities, the USPSTF committed to increasing the transparency of our work, and these efforts gained additional momentum in view of the enhanced importance of the recommendations under the new law. The USPSTF now employs an Internet-based public comment process to assist us in better crafting messages for the public and in considering additional input from experts and advocates. With these changes, though, the USPSTF remains committed to evaluating evidence free from the influence of politics, special interests, and advocacy.

Our methods continue to evolve as well. Our Procedure Manual, which can be found at http://www.USPreventiveServicesTaskForce.org/uspstf08/methods/procmanual.htm, outlines our updated process for evaluating the quality and strength of the evidence for a service, determining the net health benefit (benefit minus harms) associated with the service, and judging the level of certainty that providing these services in primary care will realize the expected level of benefit. We continue to explore the appropriate use of mathematical modeling on filling in research gaps regarding the ages at which to start and stop providing a service, and at what time intervals. In addition, we are committed to improving the communication of our recommendations to a broader audience, including patients and policymakers.

As before, the letter grade linked to each recommendation reflects the magnitude of net benefit and the strength and certainty of the evidence supporting the provision of a specific preventive service. These grades translate to practice guidance for clinicians:

- Discuss services with “A” and “B” recommendations with eligible patients and offer them as a priority.
- Discourage the use of services with “D” recommendations unless there are unusual additional considerations.
- Give lower priority to services with “C” recommendations; they need not be provided unless there are individual considerations in favor of providing the service.
- Carefully read the Clinical Considerations section for guidance for services with “I” statements, and help patients understand the uncertainty surrounding these services since the evidence is insufficient to determine net benefit.

As is true of all patient care, preventive services have become much more complex in view of ongoing research. The USPSTF realizes that clinical decisions about patients involve more complex considerations than the evidence alone; clinicians should always understand the evidence but individualize decisionmaking to the specific patient and situation. While providers and patients look for simple messages and actions, our recommendations reflect the advances in knowledge in this critical area of health services, and, in order to maximize the health benefit and decrease any health harms, we must consider the new complexity as we do for all medical services we provide. The Clinical Considerations section of each USPSTF recommendation statement helps clinicians by offering practical information so they can tailor these recommendations to individual patients.

I strongly encourage clinicians to visit the USPSTF Web site and read the complete recommendation statements for those services they provide, as the additional information can help them deliver the highest quality preventive care. In addition, the USPSTF Electronic Preventive Services Selector (ePSS), available via PDA or on the Web at http://epss.ahrq.gov, allows users to search USPSTF recommendations by patient age and other clinical characteristics.

I hope you find The Guide to Clinical Preventive Services 2010-2011 to be a useful tool as you care for patients. Based on the best medical evidence available, I am confident that by implementing these recommended services, you will help your patients live longer and healthier lives.

Ned Calonge, M.D., M.P.H.

Chair, U.S. Preventive Services Task Force