# Acknowledgments

## AHRQ Staff Supporting the USPSTF 2002-2010

- David Atkins, M.D., M.P.H.
- Mary Barton, M.D., M.P.P.
- Joel Boches
- Helen Burstin, M.D., M.P.H.
- Robert Cosby, Ph.D.
- Mackenzie Cross
- Ellen Crown
- Sandra K. Cummings
- Elizabeth Edgerton, M.D., M.P.H.
- Farah Englert
- Saeed Fatemi
- Kenneth Fink, M.D., M.G.A., M.P.H.
- Janice Genevro, Ph.D., M.S.W.
- Barbara Gordon
- Margi Grady
- Janelle Guirguis-Blake, M.D.
- William Hyde, M.L.S.
- Patrik Johansson, M.D.
- Hazel Keimowitz, M.A.
- Kristie Kiser
- David Lanier, M.D.
- Biff LeVee
- Kenneth Lin, M.D.
- Morgan Liscinsky
- Iris Mabry, M.D., M.P.H.
- Corey Mackison, M.S.A.
- Andrew Marshall
- David Meyers, M.D.
- Tess Miller, Dr.P.H.
- Emily Moser
- Kevin Murray
- Barbara Najar, M.P.H.
- Lisa Nicolella
- Nilam Patel, M.P.H.
- Amy Pfeiffer
- Kathryn Ramage
- Gurvaneet Randhawa, M.D., M.P.H.
- Eve Shapiro
- Randie Siegel, M.S.
- Jean Slutsky, P.A., M.S.P.H.
- Marion Torchia, M.L.S., M.A.
- Tricia Trinité, M.S.P.H., A.P.R.N.
- Gloria Washington
- Rachel Weinstein
- Claire Weschler, M.S.Ed.
- Tracy Wolff, M.D., M.P.H.

## Evidence-Based Practice Centers Supporting the USPSTF 2002-2010

The following researchers working through four AHRQ Evidence-Based Practice Centers prepared systematic evidence reviews and evidence summaries as resources on topics under consideration by the USPSTF.

### Oregon Evidence-Based Practice Center

Bhaskar Arora, M.D.; Sarah Baird, M.S.; Howard Balshem, M.S.; Vance Bauer, M.A.; Tracy Beil, M.S.; Ian Blazina, M.P.H.; Christina Bougatsos, B.S.; David Buckley, M.D.; Jessica Burnett; Taryn Cardenas, B.S.; Susan Carson, M.P.H.; Benjamin K.S. Chan, M.S.; Roger Chou, M.D.; Elizabeth Clark, M.D., M.P.H; Tracy Dana, M.L.S.; Robert Davis, M.D., M.P.H.; Stephanie Detlefsen, M.D.; Elizabeth Eckstrom, M.D.; Karen B. Eden, Ph.D.; Michelle Eder, Ph.D.; Craig Fleming, M.D.; Michele Freeman, M.P.H.; Rochele Fu, Ph.D.; Betsy Garlitz, M.D.; Nancy Glass, Ph.D., M.P.H., R.N.; Kenneth Gleitsmann, M.D.; Rachel Gold, Ph.D., M.P.H; Carla A. Green, Ph.D., M.P.H.; Jessica Griffin, M.A.; Jeanne-Marie Guise, M.D., M.P.H.; Andrew Hamilton, M.S., M.L.S.; Elizabeth Haney, M.D; Emily Harris, Ph.D., M.P.H.; Mark Helfand, M.D., M.P.H.; Theresa Hillier, M.D., M.S.; Rebecca Holmes, M.D., M.S.; Laurie Huffman, M.S.; Linda Humphrey, M.D., M.P.H.; Devan Kansagara, M.D.; Tanya Kapka, M.D., M.P.H.; P. Todd Korthuis, M.D., M.P.H; Kathryn Pyle Krages, M.A.; Erin Leblanc, M.D., M.P.H.; Beth Liles, M.D.; Jennifer Lin, M.D.; Kevin W. Lutz, M.F.A.; Yasmin McInerney, M.D.; Yvonne Michael, Sc.D.; Jill Miller, M.D.; Cynthia D. Morris, Ph.D., M.P.H.; Arpana Naik, M.D.; Heidi D. Nelson, M.D., M.P.H.; Rebecca Newton-Thompson, M.D., M.Sc.; Susan Norris, M.D., M.P.H.; Peggy Nygren, M.S.; Michelle Pappas, B.A.; Rita Panosca, M.D.; Kathy Pedula, M.S.; Leslie Perdue, M.P.H; Daphne Plaut, M.L.S.; Michael R. Polen, Ph.D.; Elizabeth O'Connor, Ph.D.; Gary Rischitelli, M.D., J.D., M.P.H.; Cheryl Ritenbaugh, Ph.D., M.P.H.; Kevin Rogers, M.D.; Bruin Rugge, M.D., M.P.H.; Somnath Saha, M.D., M.P.H.; Caitlyn Senger, M.P.H.; Scott A. Shipman, M.D., M.P.H.; M. E. Beth Smith, D.O.; Paula R. Smith, R.N., B.S.N.; Ariel K. Smits, M.D., M.P.H.; Robert Steiner M.D.; Kelly Streit, M.S., R.D.; Lina M.A. Takano, M.D., M.S.; Kari Tyne, M.D.; Kimberly Vesco, M.D., M.P.H.; Kim Villemyer, B.A.; Miranda Walker, M.A..; Carolyn Westhoff, M.D., M.Sc.; Evelyn P. Whitlock, M.D., M.P.H.; Selvi B.Williams, M.D., M.P.H.; Jennifer Wisdom, Ph.D., M.P.H.; Sarah Zuber, M.S.W.

### RTI International/University of North Carolina Evidence-Based Practice Center

Alice Ammerman, Dr.P.H., R.D.; James D. Bader, D.D.S., M.P.H.; Rainer Beck, M.D.; John F. Boggess, M.D.; Malaz Boustani, M.D., M.P.H.; Seth Brody, M.D.; Audrina J. Bunton; Katrina Donahue, M.D., M.P.H.; Louise Fernandez, P.A.-C., R.D., M.P.H.; Kenneth Fink, M.D., M.G.A., M.P.H.; Carol Ford, M.D.; Angela Fowler-Brown, M.D.; Bradley N. Gaynes, M.D., M.P.H.; Paul Godley, M.D., M.P.H.; Susan A. Hall, M.S.; Laura Hanson, M.D., M.P.H.; Russell Harris, M.D., M.P.H.; Katherine E.Hartmann, M.D., Ph.D.; Michael Hayden, M.D.; M. Brian Hemphill, M.D.; Alissa Driscoll Jacobs, M.S., R.D.; Jana Johnson; Linda Kinsinger, M.D., M.P.H.; Carol Krasnov; Ramesh Krishnaraj; Carole M. Lannon, M.D., M.P.H.; Carmen Lewis, M.D., M.P.H.; Kathleen N. Lohr, Ph.D.; Linda J. Lux, M.P.A.; Kathleen McTigue, M.D., M.P.H.; Catherine Mills, M.A.; Kavita Nanda, M.D., M.H.S.; Carla Nester, M.D.; Britt Peterson, M.D., M.P.H.; Christopher J. Phillips, M.D., M.P.H.; Michael Pignone, M.D., M.P.H.; Mark Pletcher, M.D., M.P.H.; Saif S. Rathore; Melissa Rich, M.D.; Gary Rozier, D.D.S.; Jerry L. Rushton, M.D., M.P.H.; Lucy A. Savitz; Joe Scattoloni; Stacey Sheridan, M.D., M.P.H.; Sonya Sutton, B.S.P.H.; Jeffrey A. Tice, M.D.; Suzanne L. West, Ph.D.; B. Lynn Whitener, Dr.P.H., M.S.L.S.; Margaret Wooddell, M.A.; Dennis Zolnoun, M.D.

### University of Ottawa Evidence-Based Practice Center

Nicholas Barrowman, Ph.D.; Catherine Code, M.D., F.R.C.P.C.; Catherine Dubé, M.D., M.Sc., F.R.C.P.C.; Gabriela Lewin, M.D.; David Moher, Ph.D.; Alaa Rostom, M.D., M.Sc., F.R.C.P.C.; Margaret Sampson, M.I.L.S.; Alexander Tsertsvadze, M.D., M.Sc.

### Tufts - New England Medical Center Evidence-Based Practice Center

Priscilla Chew; Mei Chung, M.P.H.; Deirdre DeVine; Stanley Ip, M.D.; Joseph Lau, M.D.; Gowri Raman, M.D.; Thomas Trikalinos, M.D., Ph.D.

## Liaisons to the USPSTF

Primary care partners include:

- American Academy of Family Physicians (AAFP)
- American Academy of Nurse Practitioners (AANP)
- American Academy of Pediatrics (AAP)
- American Academy of Physician Assistants (AAPA)
- American Congress of Obstetricians and Gynecologists (ACOG)
- American College of Physicians (ACP)
- American College of Preventive Medicine (ACPM)
- American Osteopathic Association (AOA)
- National Association of Pediatric Nurse Practitioners (NAPNAP)

Policy, population, and quality improvement partners include:

- America's Health Insurance Plans (AHIP)
- AARP
- National Committee for Quality Assurance (NCQA)

Federal partners include:

- Centers for Disease Control and Prevention (CDC)
- Centers for Medicare & Medicaid Services (CMS)
- U.S. Food and Drug Administration (FDA)
- Health Resources and Services Administration (HRSA)
- Indian Health Service (IHS)
- National Institutes of Health (NIH)
- Veteran's Health Administration (VHA)
- Department of Defense/Military Health System (DoD/MHS)
- Office of Disease Prevention and Health Promotion (ODPHP)
- Office of the Surgeon General