# Preventive Services Recommended by the USPSTF

Preventive Services Recommended by the USPSTF

The U.S. Preventive Services Task Force (USPSTF) recommends that clinicians discuss these preventive services with eligible patients and offer them as a priority. All these services have received an “A” or a “B” (recommended) grade from the Task Force.

For definitions of all grades used by the USPSTF, see Appendix A (beginning on P. 212). The full listings of all USPSTF recommendations for adults and children are in Section 2 (beginning on P. 11) and Section 3 (beginning on P. 179).

Recommendation | Adults | | Special Populations
Recommendation | Men | Women | Pregnant Women | Children
Abdominal Aortic Aneurysm, Screening 1 | ✓
Alcohol Misuse Screening and Behavioral Counseling Interventions | ✓ | ✓ | ✓
Aspirin for the Prevention of Cardiovascular Disease 2 | ✓ | ✓
Asymptomatic Bacteriuria in Adults, Screening 3 | | | ✓
Breast Cancer, Screening 4 | | ✓
Breast and Ovarian Cancer Susceptibility, Genetic Risk Assessment and BRCA Mutation Testing 5 | | ✓
Breastfeeding, Primary Care Interventions to Promote 6 | | ✓ | ✓
Cervical Cancer, Screening 7 | | ✓
Chlamydial Infection, Screening 8 | | ✓ | ✓
Colorectal Cancer, Screening 9 | ✓ | ✓
Congenital Hypothyroidism, Screening 10 | | | | ✓
Dental Caries in Preschool Children, Prevention 11 | | | | ✓
Depression (Adults), Screening 12 | ✓ | ✓
Diet, Behavioral Counseling in Primary Care to Promote a Healthy 13 | ✓ | ✓
Gonorrhea, Screening 14 | | ✓ | ✓
Gonorrhea, Prophylactic Medication 15 | | | | ✓
Hearing Loss in Newborns, Screening 16 | | | | ✓
Hepatitis B Virus Infection, Screening 17 | | | ✓
High Blood Pressure, Screening | ✓ | ✓
HIV, Screening 18 | ✓ | ✓ | ✓ | ✓
Iron Deficiency Anemia, Prevention 19 | | | | ✓
Iron Deficiency Anemia, Screening 20 | | | ✓
Lipid Disorders in Adults, Screening 21 | ✓ | ✓
Major Depressive Disorder in Children and Adolescents, Screening 22 | | | | ✓
Obesity in Adults, Screening 23 | ✓ | ✓
Osteoporosis in Postmenopausal Women, Screening 24 | | ✓
Phenylketonuria, Screening 25 | | | | ✓
Rh (D) Incompatibility, Screening 26 | | | ✓
Sexually Transmitted Infections, Counseling 27 | ✓ | ✓ | | ✓
Sickle Cell Disease, Screening 28 | | | | ✓
Syphilis Infection, Screening 29 | ✓ | ✓ | ✓
Tobacco Use and Tobacco-Caused Disease, Counseling 30 | ✓ | ✓ | ✓
Type 2 Diabetes Mellitus in Adults, Screening 31 | ✓ | ✓
Visual Impairment in Children Younger than Age 5 Years, Screening 32 | | | | ✓

1 One-time screening by ultrasonography in men aged 65 to 75 who have ever smoked.

2 When the potential harm of an increase in gastrointestinal hemorrhage is outweighed by a potential benefit of a reduction in myocardial infarctions (men aged 45–79 years) or in ischemic strokes (women aged 55–79 years).

3 Pregnant women at 12–16 weeks gestation or at first prenatal visit, if later.

4 Mammography every 1–2 years for women 40 and older.

5 Refer women whose family history is associated with an increased risk for deleterious mutations in BRCA1 or BRCA2 genes for genetic counseling and evaluation for BRCA testing.

6 Interventions during pregnancy and after birth to promote and support breastfeeding.

7 Women aged 21–65 who have been sexually active and have a cervix.

8 Sexually active women 24 and younger and other asymptomatic women at increased risk for infection. Asymptomatic pregnant women 24 and younger and others at increased risk.

9 Adults aged 50–75 using fecal occult blood testing, sigmoidoscopy, or colonoscopy.

10 Newborns.

11 Prescribe oral fluoride supplementation at currently recommended doses to preschool children older than 6 months whose primary water source is deficient in fluoride.

12 In clinical practices with systems to assure accurate diagnoses, effective treatment, and follow-up.

13 Adults with hyperlipidemia and other known risk factors for cardiovascular and diet-related chronic disease.

14 Sexually active women, including pregnant women 25 and younger, or at increased risk for infection.

15 Prophylactic ocular topical medication for all newborns against gonococcal ophthalmia neonatorum.

16 Newborns.

17 Pregnant women at first prenatal visit.

18 All adolescents and adults at increased risk for HIV infection and all pregnant women.

19 Routine iron supplementation for asymptomatic children aged 6 to 12 months who are at increased risk for iron deficiency anemia.

20 Routine screening in asymptomatic pregnant women.

21 Men aged 20–35 and women over age 20 who are at increased risk for coronary heart disease; all men aged 35 and older.

22 Adolescents (age 12–18) when systems are in place to ensure accurate diagnosis, psychotherapy, and follow-up.

23 Intensive counseling and behavioral interventions to promote sustained weight loss for obese adults.

24 Women 65 and older and women 60 and older at increased risk for osteoporotic fractures.

25 Newborns.

26 Blood typing and antibody testing at first pregnancy-related visit. Repeated antibody testing for unsensitized Rh (D)-negative women at 24–28 weeks gestation unless biological father is known to be Rh (D) negative.

27 All sexually active adolescents and adults at increased risk for STIs.

28 Newborns

29 Persons at increased risk and all pregnant women.

30 Tobacco cessation interventions for those who use tobacco. Augmented pregnancy-tailored counseling to pregnant women who smoke.

31 Asymptomatic adults with sustained blood pressure greater than 135/80 mg Hg.

32 To detect amblyopia, strabismus, and defects in visual acuity.