# Preface

The U.S. Preventive Services Task Force (USPSTF) is celebrating its 25th anniversary! Since 1984, the USPSTF has been conducting rigorous reviews of research evidence to create evidence-based recommendations for preventive services that should be provided in the primary care setting.

Over this quarter century of work, the USPSTF has made and maintained more than 65 separate recommendations covering services that are intended to improve health outcomes from heart disease, cancer, infectious diseases, and other conditions and events that impact the health of children, adolescents, adults, and pregnant women.

The use of these recommendations has evolved over time. The suggestion that it is not beneficial to provide all of the services available for prevention was nearly a heretical concept in U.S. medical practice when the first USPSTF started its work. Over time, individual health care providers, professional organizations, integrated health systems, health plans and insurers, and public programs, including CMS as well as groups crafting health quality measures and national health objectives, have adopted the recommendations. In 1984, the USPSTF was convened by the Department of Health and Human Services’ Assistant Secretary for Health and charged with reviewing the scientific evidence for clinical preventive services and developing evidence-based recommendations for the health care community. The primary audience for the USPSTF’s work remains primary care clinicians, and the recommendations are now considered by many to provide definitive standards for preventive services.

Our methods also have evolved over time. Today, the USPSTF evaluates the quality and strength of the evidence for the service, the net health benefit (benefit minus harms) associated with the service, and the level of certainty that this level of benefit will be realized if these services are provided in primary care. This process is outlined in our Procedure Manual, which can be found at http://www.ahrq.gov/clinic/uspstf08/methods/procmanual.htm.

All recommendation are linked to a letter grade that reflects the magnitude of net benefit and the strength and certainty of the evidence supporting the provision of a specific preventive service. The recommendation is graded from “A” (recommended) to “D” (recommended against). The Task Force gives an “I” grade when the evidence is insufficient to determine net benefit. These grades translate to practice guidance for clinicians:

- Offer or provide services with “A” and “B” recommendations to eligible patients.
- Discourage the use of services with “D” recommendations.
- Offer or provide services with “C” recommendations only if other considerations support this for an individual patient.
- For services with “I” statements, carefully read the Clinical Considerations section for guidance, and help patients understand the uncertainty surrounding these services.

The USPSTF realizes that clinical decisions about patients involve more complex considerations than the evidence alone; clinicians should always understand the evidence but individualize decisionmaking with the specific patient and situation. The Clinical Considerations section of each USPSTF Recommendation Statement helps clinicians implement the recommendations by offering practical information so they can tailor these recommendations to individual patients.

The Guide to Clinical Preventive Services 2009 is a compilation of abridged USPSTF recommendations released from 2002 to March 2009 and can be used as an evidence-based tool at the point of patient care. Some recommendations have been updated from those made by the USPSTF in previous years, while others address preventive services not previously considered by the USPSTF. Recommendations that were being updated while this edition of the Guide was being compiled, as well as the complete USPSTF recommendation statements, are available along with their supporting scientific evidence at http://www.preventiveservices.ahrq.gov.

As is true of all patient care, preventive services have become much more complex in view of ongoing research. While providers and their patients are looking for simple messages and actions, our recommendations reflect the advances in knowledge in this critical area of health services, and in order to maximize the health benefit and decrease any health harms, we must take the new complexity into consideration as we do for all medical services we provide. I strongly encourage clinicians to visit the Web site and read the complete recommendation statements for those services they provide in their practice settings, as the additional information can be useful in providing the highest quality preventive care. In addition, the USPSTF Electronic Preventive Services Selector (ePSS), available via PDA or on the Web at http://epss.ahrq.gov, allows users to search USPSTF recommendations by patient age and other clinical characteristics.

I hope you find The Guide to Clinical Preventive Services 2009 to be a useful tool as you care for patients. I am confident that by implementing these recommended services, you will help your patients live longer and healthier lives.

- Ned Calonge, M.D., M.P.H.
- Chair, U.S. Preventive Services Task Force