# Appendix C

## Acknowledgments

AHRQ Staff Supporting the USPSTF 2002–2009

David Atkins, M.D., M.P.H.

Mary Barton, M.D., M.P.P.

Joel Boches

Helen Burstin, M.D., M.P.H.

Mackenzie Cross

Ellen Crown

Sandra K. Cummings

Elizabeth Edgerton, M.D., M.P.H.

Farah Englert

Kenneth Fink, M.D., M.G.A., M.P.H.

Janice Genevro, Ph.D., M.S.W.

Barbara Gordon

Margi Grady

Janelle Guirguis-Blake, M.D.

Patrik Johansson, M.D.

Hazel Keimowitz, M.A.

Claire Kendrick, M.S.Ed.

Kristie Kiser

David Lanier, M.D.

Biff LeVee

Kenneth Lin, M.D.

Morgan Liscinsky

Iris Mabry, M.D., M.P.H.

Corey Mackison, M.S.A.

David Meyers, M.D.

Tess Miller, Dr.P.H.

Kevin Murray

Barbara Najar, M.P.H.

Nilam Patel, M.P.H.

Amy Pfeiffer

Kathryn Ramage

Gurvaneet Randhawa, M.D., M.P.H.

Eve Shapiro

Randie Siegel, M.S.

Jean Slutsky, P.A., M.S.P.H.

Marion Torchia, M.L.S., M.A.

Tricia Trinité, M.S.P.H., A.P.R.N.

Gloria Washington

Tracy Wolff, M.D., M.P.H.

Evidence-Based Practice Centers

Supporting the USPSTF 2002–2009

The following researchers working through three AHRQ Evidence-Based Practice Centers prepared systematic evidence reviews and evidence summaries as resources on topics under consideration by the USPSTF.

Oregon Evidence-Based Practice Center

Sarah Baird, M.S.; Vance Bauer, M.A.; Tracy Beil, M.S.; Christina Bougatsos, B.S.; Jessica Burnett; David Buckley, M.D.; Taryn Cardenas, B.S.; Susan Carson, M.P.H.; Benjamin K.S. Chan, M.S.; Roger Chou, M.D.; Elizabeth Clark, M.D., M.P.H; Tracy Dana, M.L.S.; Robert Davis, M.D., M.P.H.; Stephanie Detlefsen, M.D.; Karen B. Eden, Ph.D.; Michelle Eder, Ph.D.; Craig Fleming, M.D.; Michele Freeman, M.P.H.; Rochele Fu, Ph.D.; Betsy Garlitz, M.D.; Nancy Glass, Ph.D., M.P.H., R.N.; Rachel Gold, Ph.D., M.P.H; Carla A. Green, Ph.D., M.P.H.; Jeanne- Marie Guise, M.D., M.P.H.; Andrew Hamilton, M.S., M.L.S.; Elizabeth Haney, M.D; Emily Harris, Ph.D., M.P.H.; Mark Helfand, M.D., M.P.H.; Theresa Hillier, M.D., M.S.; Laurie Huffman, M.S.; Linda Humphrey, M.D., M.P.H.; Devan Kansagara, M.D.; P. Todd Korthuis, M.D., M.P.H; Kathryn Pyle Krages, M.A.; Erin Leblanc, M.D., M.P.H.; Beth Liles, M.D.; Jennifer Lin, M.D.; Kevin W. Lutz, M.F.A.; Yasmin McInerney, M.D.; Yvonne Michael, Sc.D.; Jill Miller, M.D.; Cynthia D. Morris, Ph.D., M.P.H.; Arpana Naik, M.D.; Heidi D. Nelson, M.D., M.P.H.; Rebecca Newton-Thompson, M.D., M.Sc.; Susan Norris, M.D., M.P.H.; Peggy Nygren, M.S.; Michelle Pappas, B.A.; Rita Panosca, M.D.; Kathy Pedula, M.S.; Daphne Plaut, M.L.S.; Michael R. Polen, Ph.D.; Elizabeth O’Connor, Ph.D.; Gary Rischitelli, M.D., J.D., M.P.H.; Cheryl Ritenbaugh, Ph.D., M.P.H.; Kevin Rogers, M.D.; Somnath Saha, M.D., M.P.H.; Scott A. Shipman, M.D., M.P.H.; Paula R. Smith, R.N., B.S.N.; Ariel K. Smits, M.D., M.P.H.; Robert Steiner M.D.; Kelly Streit, M.S., R.D.; Lina M.A. Takano, M.D., M.S.; Kari Tyne, M.D.; Kimberly Vesco, M.D., M.P.H.; Kim Villemyer, B.A.; Miranda Walker, M.A..; Carolyn Westhoff, M.D., M.Sc.; Evelyn P. Whitlock, M.D., M.P.H.; Selvi B.Williams, M.D., M.P.H.; Jennifer Wisdom, Ph.D., M.P.H.; Sarah Zuber, M.S.W.

RTI International/University of North Carolina

Evidence-Based Practice Center

Alice Ammerman, Dr.P.H., R.D.; James D. Bader, D.D.S., M.P.H.; Rainer Beck, M.D.; John F. Boggess, M.D.; Malaz Boustani, M.D., M.P.H.; Seth Brody, M.D.; Audrina J. Bunton; Katrina Donahue, M.D., M.P.H.; Louise Fernandez, PA-C, R.D., M.P.H.; Kenneth Fink, M.D., M.G.A., M.P.H.; Carol Ford, M.D.; Angela Fowler-Brown, M.D.; Bradley N. Gaynes, M.D., M.P.H.; Paul Godley, M.D., M.P.H.; Susan A. Hall, M.S.; Laura Hanson, M.D., M.P.H.; Russell Harris, M.D., M.P.H.; Katherine E.Hartmann, M.D., Ph.D.; Michael Hayden, M.D.; M. Brian Hemphill, M.D.; Alissa Driscoll Jacobs, M.S., R.D.; Jana Johnson; Linda Kinsinger, M.D., M.P.H.; Carol Krasnov; Ramesh Krishnaraj; Carole M. Lannon, M.D., M.P.H.; Carmen Lewis, M.D., M.P.H.; Kathleen N. Lohr, Ph.D.; Linda J. Lux, M.P.A.; Kathleen McTigue, M.D., M.P.H.; Catherine Mills, M.A.; Kavita Nanda, M.D., M.H.S.; Carla Nester, M.D.; Britt Peterson, M.D., M.P.H.; Christopher J. Phillips, M.D., M.P.H.; Michael Pignone, M.D., M.P.H.; Mark Pletcher, M.D., M.P.H.; Saif S. Rathore; Melissa Rich, M.D.; Gary Rozier, D.D.S.; Jerry L. Rushton, M.D., M.P.H.; Lucy A. Savitz; Joe Scattoloni; Stacey Sheridan, M.D., M.P.H.; Sonya Sutton, B.S.P.H.; Jeffrey A. Tice, M.D.; Suzanne L. West, Ph.D.; B. Lynn Whitener, Dr.P.H., M.S.L.S.; Margaret Wooddell, M.A.; Dennis Zolnoun, M.D.

University of Ottawa Evidence-Based Practice Center

Nicholas Barrowman, Ph.D.; Catherine Code, M.D., F.R.C.P.C.; Catherine Dubé, M.D., M.Sc., F.R.C.P.C.; Gabriela Lewin, M.D.; David Moher, Ph.D.; Alaa Rostom, M.D., M.Sc., F.R.C.P.C.; Margaret Sampson, M.I.L.S.; Alexander Tsertsvadze, M.D., M.Sc.

Liaisons to the USPSTF

Professional Organizations

American Academy of Family Physicians

American Academy of Nurse Practitioners

American Academy of Pediatrics

American Academy of Physician Assistants

American College of Obstetricians and Gynecologists

American College of Physicians

American College of Preventive Medicine

American Medical Association

American Osteopathic Association

America’s Health Insurance Plans

National Committee for Quality Assurance

National Organization of Nurse Practitioner Faculties

Government Agencies

Centers for Disease Control and Prevention

Centers for Medicare & Medicaid Services

Department of Veterans Affairs

Health Resources and Services Administration

Indian Health Services

Military Health System

National Institutes of Health

Office of Disease Prevention and Health Promotion

U.S. Food and Drug Administration