# Appendix B

## Members of the U.S. Preventive Services Task Force 2002–2009

Janet D. Allan, Ph.D., R.N., C.S., F.A.A.N.

School of Nursing, University of Maryland, Baltimore, Baltimore, MD

Alfred O. Berg, M.D., M.P.H.

University of Washington, Seattle, WA

Ned Calonge, M.D., M.P.H.

Colorado Department of Public Health and Environment, Denver, CO

Susan Curry, Ph.D.

College of Public Health, University of Iowa, Iowa City, IA

Thomas G. DeWitt, M.D.

Department of Pediatrics, Children’s Hospital Medical Center, Cincinnati, OH

Allen J. Dietrich, M.D.

Dartmouth Medical School, Hanover, NH

Paul S. Frame, M.D.

Tri-County Family Medicine, Cohocton, NY

Joxel Garcia, M.D., M.B.A.

Pan American Health Organization, Washington, DC

Leon Gordis, M.D., Dr. P.H.

Johns Hopkins Bloomberg School of Public Health, Baltimore, MD

Kimberly D. Gregory, M.D., M.P.H.

Cedars-Sinai Medical Center, Los Angeles, CA

David Grossman, M.D., M.P.H.

Center for Health Studies, Group Health Cooperative, University of Washington, Seattle, WA

Russell Harris, M.D., M.P.H.

University of North Carolina School of Medicine, Chapel Hill, NC

Charles J. Homer, M.D., M.P.H.

National Initiative for Children’s Healthcare Quality, Boston, MA

George Isham, M.D., M.S.

HealthPartners, Minneapolis, MN

Mark S. Johnson, M.D., M.P.H.

New Jersey Medical School, University of Medicine and Dentistry of New Jersey, Newark, NJ

Kenneth Kizer, M.D., M.P.H.

National Quality Forum, Washington, DC

Jonathan D. Klein, M.D., M.P.H.

University of Rochester, Rochester, NY

Tracy A. Lieu, M.D., M.P.H.

Harvard Pilgrim Health Care and Harvard, Medical School, Boston, MA

Michael L. LeFevre, M.D., M.S.P.H.

University of Missouri School of Medicine, Columbia, MO

Rosanne Leipzig, M.D., Ph.D.

Mount Sinai School of Medicine, New York, NY

Carol Loveland-Cherry, Ph.D., R.N., F.A.A.N.

School of Nursing, University of Michigan, Ann Arbor, MI

Lucy N. Marion, Ph.D., R.N.

School of Nursing, Medical College of Georgia, Augusta, GA

Bernadette Melnyk, Ph.D., R.N., C.P. N.P./N.P.P.

College of Nursing & Healthcare Innovation, Arizona State University, Phoenix, AZ

Virginia A. Moyer, M.D., M.P.H.

University of Texas Health Science Center, Houston, TX

Cynthia D. Mulrow, M.D., M.Sc.

University of Texas Health Science Center, Audie L. Murphy Memorial Veterans Hospital, San Antonio, TX

Wanda Nicholson, M.D., M.P.H., M.B.A

Johns Hopkins School of Medicine and Bloomberg School of Public Health, Baltimore, MD

Judith K. Ockene, Ph.D., M.Ed.

University of Massachusetts Medical School, Worcester, MA

C. Tracy Orleans, Ph.D.

The Robert Wood Johnson Foundation, Princeton, NJ

Jeffrey F. Peipert, M.D., M.P.H.

Women and Infants’ Hospital, Providence, RI

Nola J. Pender, Ph.D., R.N.

School of Nursing, University of Michigan, Ann Arbor, MI

Diana B. Petitti, M.D., M.P.H.

Fulton School of Engineering, Arizona State University, Tempe, AZ

George F. Sawaya, M.D.

University of California, San Francisco, San Francisco, CA

J. Sanford (Sandy) Schwartz, M.D.

University of Pennsylvania School of Medicine and Wharton School, Philadelphia, PA

Harold C. Sox, Jr., M.D.

Dartmouth-Hitchcock Medical Center, Lebanon, NH

Albert L. Siu, M.D., M.S.P.H.

Mount Sinai Medical Center, New York, NY

Steven M. Teutsch, M.D., M.P.H.

Merck and Company, Inc., West Point, PA

Carolyn Westhoff, M.D., M.Sc.

Columbia University, New York, NY

Timothy Wilt, M.D., M.P.H.

Minneapolis VA Medical Center, University of Minnesota, Minneapolis, MN

Steven H. Woolf, M.D., M.P.H.

Virginia Commonwealth University, Fairfax, VA

Barbara P. Yawn, M.D., M.S.P.H., M.Sc.

Olmstead Medical Center, Rochester, MN