# Appendixes

Appendix A

Appendix B

Appendix C

Appendix D. Advisory Committee on Immunization Practices Recommended Immunization Schedules