# Recommendations for Children

All recommendation statements in this Guide are abridged. To see the full recommendation statements and recommendations published after 2006, go to http://www.ahrq.gov/clinic/uspstf/uspstopics.htm.

Screening for Elevated Blood Lead Levels in Children and Pregnant Women

Prevention of Dental Caries in Preschool Children

Screening for Developmental Dysplasia of the Hip

Screening for Idiopathic Scoliosis in Adolescents

Newborn Hearing Screening

Screening and Interventions for Overweight in Children and Adolescents

Screening for Speech and Language Delay in Preschool Children

Screening for Visual Impairment in Children Younger Than Age 5 Years