# Recommendations for Adults

All recommendation statements in this Guide are abridged. To see the full recommendation statements and recommendations published after 2006, go to http://www.ahrq.gov/clinic/uspstf/uspstopics.htm.

Cancer

Heart and Vascular Diseases

Infectious Diseases

Injury and Violence

Mental Health Conditions and Substance Abuse

Metabolic, Nutritional, and Endocrine Conditions

Musculoskeletal Conditions

Obstetric and Gynecologic Conditions

Vision Disorders