# Preventive Services Recommended by the USPSTF

All recommendation statements in this Guide are abridged. To see the full recommendation statements and recommendations published after 2006, go to http://www.ahrq.gov/clinic/uspstf/uspstopics.htm.

Table 1 Preventive Services Recommended by the USPSTF

The U.S. Preventive Services Task Force (USPSTF) recommends that clinicians discuss these preventive services with eligible patients and offer them as a priority. All these services have received an “A” (strongly recommended) or a “B” (recommended) grade from the Task Force.
For definitions of all grades used by the USPSTF, see the inside front cover. The full listings of all USPSTF recommendations for adults and children are in Section 2 (P. 9) and Section 3 (P. 179).
| Adults | | Special Populations
Recommendation | Men | Women | Pregnant Women | Children
Abdominal Aortic Aneurysm, Screening^1^ | ✓
Alcohol Misuse Screening and Behavioral Counseling Interventions | ✓ | ✓ | ✓
Aspirin for the Primary Prevention of Cardiovascular Events^2^ | ✓ | ✓
Bacteriuria, Screening for Asymptomatic | | | ✓
Breast Cancer, Chemoprevention^3^ | | ✓
Breast Cancer, Screening^4^ | | ✓
Breast and Ovarian Cancer Susceptibility, Genetic Risk Assessment and BRCA Mutation Testing^5^ | | ✓
Breastfeeding, Behavioral Interventions to Promote^6^ | | ✓ | ✓
Cervical Cancer, Screening^7^ | | ✓
Chlamydial Infection, Screening^8^ | | ✓ | ✓
Colorectal Cancer, Screening^9^ | ✓ | ✓
Dental Caries in Preschool Children, Prevention^10^ | | | | ✓
Depression, Screening^11^ | ✓ | ✓
Diabetes Mellitus in Adults, Screening for Type 2^12^ | ✓ | ✓
Diet, Behavioral Counseling in Primary Care to Promote a Healthy^13^ | ✓ | ✓
Gonorrhea, Screening^14^ | | ✓ | ✓
Gonorrhea, Prophylactic Medication^15^ | | | | ✓
Hepatitis B Virus Infection, Screening^16^ | | | ✓
High Blood Pressure, Screening | ✓ | ✓
HIV, Screening^17^ | ✓ | ✓ | ✓ | ✓
Iron Deficiency Anemia, Prevention^18^ | | | | ✓
Iron Deficiency Anemia, Screening^19^ | | | ✓
Lipid Disorders, Screening^20^ | ✓ | ✓
Obesity in Adults, Screening^21^ | ✓ | ✓
Osteoporosis in Postmenopausal Women, Screening^22^ | | ✓
Rh (D) Incompatibility, Screening^23^ | | | ✓
Syphilis Infection, Screening^24^ | ✓ | ✓ | ✓
Tobacco Use and Tobacco-Caused Disease, Counseling^25^ | ✓ | ✓ | ✓
Visual Impairment in Children Younger than Age 5 Years, Screening^26^ | | | | ✓

1 One-time screening by ultrasonography in men aged 65 to 75 who have ever smoked.

2 Adults at increased risk for coronary heart disease.

3 Discuss with women at high risk for breast cancer and at low risk for adverse effects of chemoprevention.

4 Mammography every 1–2 years for women 40 and older.

5 Refer women whose family history is associated with an increased risk for deleterious mutations in BRCA1 or BRCA2 genes for genetic counseling and evaluation for BRCA testing.

6 Structured education and behavioral counseling programs.

7 Women who have been sexually active and have a cervix.

8 Sexually active women 25 and younger and other asymptomatic women at increased risk for infection. Asymptomatic pregnant women 25 and younger and others at increased risk.

9 Men and women 50 and older.

10 Prescribe oral fluoride supplementation at currently recommended doses to preschool children older than 6 months whose primary water source is deficient in fluoride.

11 In clinical practices with systems to assure accurate diagnoses, effective treatment, and follow-up.

12 Adults with hypertension or hyperlipidemia.

13 Adults with hyperlipidemia and other known risk factors for cardiovascular and diet-related chronic disease.

14 All sexually active women, including those who are pregnant, at increased risk for infection (that is, if they are young or have other individual or population risk factors).

15 Prophylactic ocular topical medication for all newborns against gonococcal ophthalmia neonatorum.

16 Pregnant women at first prenatal visit.

17 All adolescents and adults at increased risk for HIV infection and all pregnant women.

18 Routine iron supplementation for asymptomatic children aged 6 to 12 months who are at increased risk for iron deficiency anemia.

19 Routine screening in asymptomatic pregnant women.

20 Men 35 and older and women 45 and older. Younger adults with other risk factors for coronary disease. Screening for lipid disorders to include measurement of total cholesterol and high-density lipoprotein cholesterol.

21 Intensive counseling and behavioral interventions to promote sustained weight loss for obese adults.

22 Women 65 and older and women 60 and older at increased risk for osteoporotic fractures.

23 Blood typing and antibody testing at first pregnancy-related visit. Repeated antibody testing for unsensitized Rh (D)-negative women at 24–28 weeks gestation unless biological father is known to be Rh (D) negative.

24 Persons at increased risk and all pregnant women.

25 Tobacco cessation interventions for those who use tobacco. Augmented pregnancy-tailored counseling to pregnant women who smoke.

26 To detect amblyopia, strabismus, and defects in visual acuity.