# Index. Recommendations, Alphabetical by Topic

Abdominal Aortic Aneurysm, Screening for | 55
Alcohol Misuse, Screening and Behavioral Counseling Interventions in Primary Care to Reduce | 105
Aspirin for the Primary Prevention of Cardiovascular Events | 59
Back Pain in Adults, Primary Care Interventions to Prevent Low | 157
Bacterial Vaginosis in Pregnancy, Screening for | 165
Bacteriuria, Screening for Asymptomatic | 77
Bladder Cancer in Adults, Screening for | 11
Blood Lead Levels in Children and Pregnant Women, Screening for Elevated | 181
Breast and Ovarian Cancer Susceptibility, Genetic Risk Assessment and BRCA Mutation Testing for | 13
Breast Cancer, Chemoprevention of | 17
Breast Cancer, Screening for | 23
Breastfeeding, Behavioral Interventions to Promote | 167
Cervical Cancer, Screening for | 26
Chlamydial Infection, Screening for | 79
Colorectal Cancer, Screening for | 32
Coronary Heart Disease, Screening for | 64
Dementia, Screening for | 112
Dental Caries in Preschool Children, Prevention of | 185
Depression, Screening for | 114
Developmental Dysplasia of the Hip, Screening for | 187
Diabetes Mellitus in Adults, Screening for Type 2 | 152
Diet, Behavioral Counseling in Primary Care to Promote a Healthy | 125
Family and Intimate Partner Violence, Screening for | 101
Genital Herpes, Screening for | 83
Gestational Diabetes Mellitus, Screening for | 170
Glaucoma, Screening for | 175
Gonorrhea, Screening for | 86
Hemochromatosis, Screening for | 131
Hepatitis B Virus Infection, Screening for | 90
Hepatitis C in Adults, Screening for | 92
High Blood Pressure, Screening for | 67
HIV, Screening for | 94
Hormone Therapy for the Prevention of Chronic Conditions in Postmenopausal Women | 135
Iron Deficiency Anemia, Screening for and Iron Supplementation | 138
Lipid Disorders in Adults, Screening for | 71
Lung Cancer Screening | 36
Newborn Hearing Screening | 192
Obesity in Adults, Screening for | 142
Oral Cancer, Screening for | 38
Osteoporosis in Postmenopausal Women, Screening for | 159
Ovarian Cancer, Screening for | 39
Overweight in Children and Adolescents, Screening and Interventions for | 194
Pancreatic Cancer, Screening for | 41
Peripheral Arterial Disease, Screening for | 75
Physical Activity, Behavioral Counseling in Primary Care to Promote | 147
Prostate Cancer, Screening for | 43
Rh (D) Incompatibility, Screening for | 172
Scoliosis in Adolescents, Screening for Idiopathic | 190
Skin Cancer, Counseling to Prevent | 46
Skin Cancer, Screening for | 48
Speech and Language Delay in Preschool Children, Screening for | 197
Suicide Risk, Screening for | 118
Syphilis Infection, Screening for | 98
Testicular Cancer, Screening for | 50
Thyroid Disease, Screening for | 150
Tobacco Use and Tobacco-Caused Disease, Counseling to Prevent | 120
Visual Impairment in Children Younger Than Age 5 Years, Screening for | 199
Vitamin Supplementation to Prevent Cancer and Cardiovascular Disease, Routine | 52

AHRQ's Electronic Preventive Services Selector (ePSS)

Bringing the prevention information clinicians need—recommendations, clinical considerations, and selected practice tools—to the point of care.

The ePSS helps you identify and select customized screening, counseling, and preventive medication services based on specific patient characteristics.

More Resources on Preventive Services

Prevention Dissemination and Implementation (Put Prevention Into Practice) aims to improve delivery of appropriate clinical preventive services. The program disseminates the USPSTF recommendations in multiple formats and facilitates health care delivery systems' implementation of evidence-based preventive services through partnerships, communication, user-driven tools, and outreach. For more information, go to http://www.ahrq.gov/clinic/ppipx.htm.

The Guide to Community Preventive Services provides recommendations on population-based interventions to promote health and prevent disease, injury, disability, and premature death. Recommendations are promulgated by the Task Force on Community Preventive Services, an independent group appointed by the Director of the Centers for Disease Control and Prevention. For information, go to http://www.thecommunityguide.org.

The National Guideline Clearinghouse™ (NGC) is a database of evidence-based clinical practice guidelines and related documents. To access, go to http://www.guideline.gov.

The Adult Preventive Care Timeline, based on USPSTF recommendations, is an at-a-glance wall poster, showing which preventive services your patients need, and when. To order, call the AHRQ Publications Clearinghouse at 1-800-358-9295 or send an e-mail to ahrqpubs@ahrq.hhs.gov.