# Acknowledgments

AHRQ Staff Supporting the USPSTF 2001-2006

David Atkins, M.D., M.P.H.

Mary Barton, M.D., M.P.P.

Dana Best, M.D., M.P.H.

Joel Boches

Helen Burstin, M.D., M.P.H.

Mackenzie Cross

Sandra K. Cummings

Elizabeth Edgerton, M.D., M.P.H.

Farah Englert

Kenneth Fink, M.D., M.G.A., M.P.H.

Janice L. Genevro, Ph.D., M.S.W.

Barbara Gordon

Margi Grady

Janelle Guirguis-Blake, M.D.

Patrik Johansson, M.D.

Heather Johnson

Douglas Kamerow, M.D., M.P.H.

Hazel Keimowitz, M.A.

Claire Kendrick, M.S.Ed.

David Lanier, M.D.

Kenneth Lin, M.D.

Iris Mabry, M.D., M.P.H.

Corey Mackison, M.S.A.

David Meyers, M.D.

Tess Miller, Dr.P.H.

Kevin Murray

Barbara Najar, M.P.H.

Bridget O'Connell

Nilam Patel, M.P.H.

Amy Pfeiffer

Gurvaneet Randhawa, M.D., M.P.H.

Stacia Sanvick

Eve Shapiro

Randie Siegel, M.S.

Jean Slutsky, P.A., M.S.P.H.

Kristie Smith

Marion Torchia

Tricia Trinité, M.S.P.H., A.P.R.N.

Tracy Wolff, M.D., M.P.H.

Evidence-Based Practice Centers

Supporting the USPSTF 2001-2006

The following researchers working through three AHRQ Evidence-Based Practice Centers prepared systematic evidence reviews and evidence summaries as resources on topics under consideration by the USPSTF.

Oregon Evidence-Based Practice Center

Mikel Aickin, Ph.D.; Sarah Baird, M.S.; Vance Bauer, M.A.; Tracy Beil, M.S.; Christina Bougatsos, B.S.; Jessica Burnett; David Buckley, M.D.; Taryn Cardenas, B.S.; Susan Carson, M.P.H.; Benjamin K.S. Chan, M.S.; Roger Chou, M.D.; Elizabeth Clark, M.D., M.P.H; Robert Davis, M.D., M.P.H.; Stephanie Detlefsen, M.D.; Karen B. Eden, Ph.D.; Michelle Eder, Ph.D.; Craig Fleming, M.D.; Michele Freeman, M.P.H.; Rochele Fu, Ph.D.; Nancy Glass, Ph.D., M.P.H., R.N.; Rachel Gold, Ph.D., M.P.H; Carla A. Green, Ph.D., M.P.H.; Jeanne-Marie Guise, M.D., M.P.H.; Andrew Hamilton, M.S., M.L.S.; Elizabeth Haney, M.D; Emily Harris, Ph.D., M.P.H.; Mark Helfand, M.D., M.P.H.; Theresa Hillier, M.D., M.S.; Laurie Huffman, M.S.; Linda Humphrey, M.D., M.P.H.; Devan Kansagara, M.D.; P. Todd Korthuis, M.D., M.P.H; Kathryn Pyle Krages, M.A.; Erin Leblanc, M.D., M.P.H.; Beth Liles, M.D.; Jennifen Lin, M.D.; Susan Mahon, M.P.H.; Yasmin McInerney, M.D.; Heather McPhillips, M.D., M.P.H.; Yvonne Michael, Sc.D.; Jill Miller, M.D.; Cynthia D. Morris, Ph.D., M.P.H.; Cynthia Mulrow, M.D., M.Sc.; Arpana Naik, M.D.; Heidi D. Nelson, M.D., M.P.H.; Rebecca Newton-Thompson, M.D., M.Sc.; Susan Norris, M.D., M.P.H.; Peggy Nygren, M.S.; Tracy Orleans, Ph.D.; Valerie Palda, M.D., M.P.H.; Rita Panosca, M.D.; Nola Pender, Ph.D., R.N., F.A.A.N.;, Jeffrey Piepert, M.D., M.P.H.; Daphne Plaut, M.L.S.; Michael R. Polen, Ph.D.; Elizabeth O'Connor, Ph.D.; Gary Rischitelli, M.D., J.D., M.P.H.; Cheryl Ritenbaugh, Ph.D., M.P.H.; Kevin Rogers, M.D.; Somnath Saha, M.D., M.P.H.; Scott A. Shipman, M.D., M.P.H.; Paula R. Smith, R.N., B.S.N.; Ariel K. Smits, M.D., M.P.H.; Robert Steiner, M.D.; Kelly Streit, M.S., R.D.; Lina M.A. Takano, M.D., M.S.; Diane Thompson, M.S.; Kari Tyne, M.D.; Kimberly Vesco, M.D., M.P.H.; Kim Villemyer, B.A.; Miranda Walker, B.A.; Carolyn Westoff, M.D., M.Sc.; Evelyn P. Whitlock, M.D., M.P.H.; Selvi B.Williams, M.D., M.P.H.; Jennifer Wisdom, Ph.D., M.P.H.; Sarah Zuber, B.A.

RTI International/University of North Carolina Evidence-Based Practice Center

Alice Ammerman, Dr.P.H., R.D.; James D. Bader, D.D.S., M.P.H.; Rainer Beck, M.D.; John F. Boggess, M.D.; Malaz Boustani, M.D., M.P.H.; Seth Brody, M.D.; Audrina J. Bunton; Katrina Donahue, M.D., M.P.H.; Louise Fernandez, PA-C, R.D., M.P.H.; Kenneth Fink, M.D., M.G.A., M.P.H.; Carol Ford, M.D.; Angela Fowler-Brown, M.D.; Bradley N. Gaynes, M.D., M.P.H.; Paul Godley, M.D., M.P.H.; Susan A. Hall, M.S.; Laura Hanson, M.D., M.P.H.; Russell Harris, M.D., M.P.H.; Katherine E.Hartmann, M.D., Ph.D.; Michael Hayden, M.D.; M. Brian Hemphill, M.D.; Alissa Driscoll Jacobs, M.S., R.D.; Jana Johnson; Linda Kinsinger, M.D., M.P.H.; Carol Krasnov; Ramesh Krishnaraj; Carole M. Lannon, M.D., M.P.H.; Carmen Lewis, M.D., M.P.H.; Kathleen N. Lohr, Ph.D.; Linda J. Lux, M.P.A.; Kathleen McTigue, M.D., M.P.H.; Catherine Mills, M.A.; Kavita Nanda, M.D., M.H.S.; Carla Nester, M.D.; Britt Peterson, M.D., M.P.H.; Christopher J. Phillips, M.D., M.P.H.; Michael Pignone, M.D., M.P.H.; Mark Pletcher, M.D., M.P.H.; Saif S. Rathore; Melissa Rich, M.D.; Gary Rozier, D.D.S.; Jerry L. Rushton, M.D., M.P.H.; Lucy A. Savitz; Joe Scattoloni; Stacey Sheridan, M.D., M.P.H.; Sonya Sutton, B.S.P.H.; Jeffrey A. Tice, M.D.; Suzanne L. West, Ph.D.; B. Lynn Whitener, Dr.P.H., M.S.L.S.; Margaret Wooddell, M.A.; Dennis Zolnoun, M.D.

University of Ottawa Evidence-Based Practice Center

Nicholas Barrowman, Ph.D.; Catherine Code, M.D., F.R.C.P.C.; Catherine Dubé, M.D., M.Sc., F.R.C.P.C.; Gabriela Lewin, M.D.; David Moher, Ph.D.; Alaa Rostom, M.D., M.Sc., F.R.C.P.C.; Margaret Sampson, M.I.L.S.; Alexander Tsertsvadze, M.D., M.Sc.

Liaisons to the USPSTF

Professional Organizations

American Academy of Family Physicians

American Academy of Nurse Practitioners

American Academy of Pediatrics

American Academy of Physician Assistants

American College of Obstetricians and Gynecologists

American College of Physicians

American College of Preventive Medicine

American Medical Association

American Osteopathic Association

America's Health Insurance Plans

National Organization of Nurse Practitioner Faculties

Government Agencies

Canadian Task Force on Preventive Health Care

Centers for Disease Control & Prevention

Centers for Medicare & Medicaid Services

Health Resources and Services Administration

Indian Health Services

Military Health System

National Institutes of Health

U.S. Food and Drug Administration

VA National Center for Health Promotion and Disease Prevention