# Members of the U.S. Preventive Services Task Force 2001-2006

- Janet D. Allan, Ph.D., R.N., C.S., F.A.A.N.
- School of Nursing
- University of Maryland, Baltimore
- Baltimore, MD

- Alfred O. Berg, M.D., M.P.H.
- Department of Family Medicine
- University of Washington
- Seattle, WA

- Ned Calonge, M.D., M.P.H.
- Colorado Department of Public Health and Environment
- Denver, CO

- Thomas G. DeWitt, M.D.
- Director of the Division of General and Community Pediatrics
- Department of Pediatrics, Children's Hospital Medical Center
- Cincinnati, OH

- Paul S. Frame, M.D.
- Tri-County Family Medicine
- Cohocton, NY

- Joxel Garcia, M.D., M.B.A.
- Pan American Health Organization
- Washington, DC

- Leon Gordis, M.D., Dr. P.H.
- Epidemiology Department
- Johns Hopkins Bloomberg School of Public Health
- Baltimore, MD

- Kimberly D. Gregory, M.D., M.P.H.
- Department of Obstetrics and Gynecology
- Cedars-Sinai Medical Center
- Los Angeles, CA

- Russell Harris, M.D., M.P.H.
- University of North Carolina School of Medicine
- Chapel Hill, NC

- Charles J. Homer, M.D., M.P.H.
- National Initiative for Children's Healthcare Quality
- Boston, MA

- George Isham, M.D., M.S.
- Medical Director and Chief Health Officer
- HealthPartners
- Minneapolis, MN

- Mark S. Johnson, M.D., M.P.H.
- Department of Family Medicine
- New Jersey Medical School
- University of Medicine and Dentistry of New Jersey
- Newark, NJ

- Kenneth Kizer, M.D., M.P.H.
- National Quality Forum
- Washington, DC

- Jonathan D. Klein, M.D., M.P.H.
- Department of Pediatrics
- University of Rochester
- Rochester, NY

- Tracy A. Lieu, M.D., M.P.H.
- Department of Ambulatory
- Care and Prevention
- Harvard Pilgrim Health Care and Harvard Medical School
- Boston, MA

- Michael L. LeFevre, M.D., M.S.P.H.
- University of Missouri
- School of Medicine
- Columbia, MO

- Carol Loveland-Cherry, Ph.D., R.N., F.A.A.N.
- Office of Academic Affairs
- School of Nursing, University of Michigan
- Ann Arbor, MI

- Lucy N. Marion, Ph.D., R.N.
- School of Nursing, Medical College of Georgia
- Augusta, GA

- Virginia A. Moyer, M.D., M.P.H.
- Department of Pediatrics
- University of Texas Health Science Center
- Houston, TX

- Cynthia D. Mulrow, M.D., M.Sc.
- University of Texas Health Science Center
- Audie L. Murphy Memorial Veterans Hospital
- San Antonio, TX

- Judith K. Ockene, Ph.D., M.Ed.
- Division of Preventive and Behavioral Medicine
- University of Massachusetts Medical School
- Worcester, MA

- C. Tracy Orleans, Ph.D.
- Department of Research and Evaluation
- The Robert Wood Johnson Foundation
- Princeton, NJ

- Jeffrey F. Peipert, M.D., M.P.H.
- Women and Infants' Hospital
- Providence, RI

- Nola J. Pender, Ph.D., R.N.
- School of Nursing
- University of Michigan
- Ann Arbor, MI

- Diana B. Petitti, M.D., M.P.H.
- Kaiser Permanente Southern California
- Pasadena, CA

- George F. Sawaya, M.D.
- Department of Obstetrics, Gynecology, and Reproductive Sciences
- Department of Epidemiology and Biostatistics
- University of California, San Francisco
- San Francisco, CA

- Harold C. Sox, Jr., M.D.
- Department of Medicine
- Dartmouth-Hitchcock Medical Center
- Lebanon, NH

- Albert L. Siu, M.D., M.S.P.H.
- Brookdale Department of Geriatrics and Adult Development
- Mount Sinai Medical Center
- New York, NY

- Steven M. Teutsch, M.D., M.P.H.
- Merck and Company, Inc.
- West Point, PA

- Carolyn Westhoff, M.D., M.Sc.
- Department of Obstetrics and Gynecology
- Columbia University
- New York, NY

- Steven H. Woolf, M.D., M.P.H.
- Department of Family Practice, Preventive Medicine, and Community Health
- Virginia Commonwealth University
- Fairfax, VA

- Barbara P. Yawn, M.D., M.Sc.
- Olmstead Research Center
- Rochester, MN