# Appendices

Appendix A How the U.S. Preventive Services Task Force Grades Its Recommendations

Appendix B Members of the U.S. Preventive Services Task Force 2001-2006

Appendix C Acknowledgments

Appendix D Advisory Committee on Immunization Practices Recommended Immunization Schedules

Index. Recommendations, Alphabetical by Topic