# Vaccine-Preventable Diseases

Vaccine-Preventable Diseases: Improving Vaccination Coverage in Children, Adolescents, and Adults: A Report on Recommendations from the Task Force on Community Preventive Services

Reviews of Evidence Regarding Interventions to Improve Vaccination Coverage in Children, Adolescents, and Adults [Draft]