# Reviews of Evidence Regarding Interventions to Improve Vaccination Coverage in Children, Adolescents, and Adults [Draft]

## CONTRIBUTORS

### Coordination Team

- Task Force Member
- Alan R. Hinman, M.D., M.P.H.
- Task Force for Child Survival and Development
- Atlanta, Georgia

- Guide Staff Members
- Peter A. Briss, M.D.
- Vilma G. Carande-Kulis, M.S., Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, Georgia

- Subject Matter Experts
- Roger R. Bernier, Ph.D.
- Serigne M. Ndiaye, Ph.D.
- Lance E. Rodewald, M.D.
- Abigail M. Shefer, M.D.
- Raymond A. Strikas, M.D.
- Sheree M. Williams, Ph.D.
- Hussain R. Yusuf, M.B.B.S., M.P.H.
- National Immunization Program
- Centers for Disease Control and Prevention
- Atlanta, Georgia

### Consultation Team

- David Atkins, M.D., M.P.H.^*^
- Agency for Health Care Policy and Research
- Rockville, Maryland

- Joseph Chin, M.D., M.S.^*^
  * Task Force Member, Liaison Member, or Consultant
- Health Care Financing Administration
- Baltimore, Maryland
- Caswell A. Evans, D.D.S., M.P.H.^*^
- National Institutes of Health
- Bethesda, Maryland

- Theresa W. Gyorkos, Ph.D.
- Montreal General Hospital and McGill University
- Montreal, Quebec, Canada

- George J. Isham, M.D.^*^
- HealthPartners
- Bloomington, Minnesota

- Susan M. Lett, M.D., M.P.H.
- Massachusetts Department of Public Health
- Boston, Massachusetts

- Rose Marie Matulionis, M.S.P.H.
- Association of State and Territorial Directors of Health Promotion and Public Health Education
- Washington, DC

- Lloyd F. Novick, M.D., M.P.H.^*^
- Onondaga County Health Department
- Syracuse, New York

- Thomas N. Saari, M.D.
- University of Wisconsin
- Madison, Wisconsin

- William Schaffner, II, M.D.
- Vanderbilt University
- Nashville, Tennessee

- Susan C. Scrimshaw, Ph.D.^*^
- University of Illinois
- Chicago, Illinois

### Abstraction Team

- Sania Amr, M.D., M.S.
- Johns Hopkins School of Hygiene and Public Health
- Baltimore, Maryland

- Judith E. Gendler, M.S.
- Department of Health and Social Services
- Wilmington, Delaware

- Richard J. Gugelman, M.D., M.P.H.
- Gugelman, Melville, and Associates
- Chapel Hill, North Carolina

- Alan R. Hinman, M.D., M.P.H.
- Task Force for Child Survival and Development
- Atlanta, Georgia

- Thomas N. Saari, M.D.
- University of Wisconsin
- Madison, Wisconsin

- Sarah E. Teagle, Dr.P.H.
- Research Triangle Institute
- Research Triangle Park, North Carolina

- Peter A. Briss, M.D.
- Nino Khetsuriani, M.D., Ph.D.
- C. Dexter (Bo) Kimsey, Ph.D., M.S.E.H.
- Serigne M. Ndiaye, Ph.D.
- Abigail M. Shefer, M.D.
- Raymond A. Strikas, M.D.
- Benedict I. Truman, M.D., M.P.H.
- Seymour G. Williams
- Sheree M. Williams, Ph.D.
- Hussain R. Yusuf, M.B.B.S., M.P.H.
- Centers for Disease Control and Prevention
- Atlanta, Georgia

### Project Editors for the Guide to Community Preventive Services

- Valerie R. Johnson
- C. Kay Smith-Akin, M.Ed.^*^
  * Lead Editor of This Chapter
- Centers for Disease Control and Prevention
- Atlanta, Georgia

## NOMENCLATURE

NOMENCLATURE

AAFP | American Academy of Family Physicians
AAP | American Academy of Pediatrics
AC | average costs
ACIP | Advisory Committee on Immunization Practices
CA | cost-analysis
CDC | Centers for Disease Control and Prevention
CE | cost-effectiveness
CI | confidence interval
DHHS | U.S. Department of Health and Human Services
DT | pediatric formulation of diphtheria and tetanus toxoids
DTP | diphtheria-tetanus toxoids and pertussis vaccine
GAO | U.S. General Accounting Office
HEDIS | Healthplan Employer Data and Information Set
Hib | Haemophilus influenzae type b conjugate vaccine
MMR | measles, mumps, and rubella vaccine
OPV | oral poliovirus vaccine
Td | adult formulation of diphtheria and tetanus toxoids
VA | Veterans' Administration
WIC | Special Supplemental Nutrition Program for Women, Infants, and Children, which is administered by the U.S. Department of Agriculture

Increasing Community Demand for Vaccinations

1 Client Reminder/Recall Strongly Recommended Page 11 | Client reminder/recall interventions involve reminding members of a target population that vaccinations are due (reminders) or late (recall). Reminders differ in content and are delivered by various methods - telephone, letter, postcard, or other. Interventions that incorporate aspects of both client reminder/recall and home visits are reviewed under home-visiting interventions. Key Findings Client reminder/recall improves vaccination coverage -; - in children and adults;; - in a range of settings and populations;; - when applied at different levels of scale from individual practice settings to entire communities;; - across a range of intervention characteristics (e.g., reminder or recall; content; theoretical basis; and method of delivery); and; - whether used alone or as part of a multicomponent intervention.
2 Multicomponent Interventions That Include Education Strongly Recommended Page 13 | Multicomponent interventions that include education provide knowledge to target populations and in some instances, to vaccination providers, and use at least one other activity to improve vaccination coverage. Key Findings Multicomponent interventions that include education -; - improve vaccination coverage among children and adults;; - improve vaccination coverage in communitywide and clinic-based settings;; - improve vaccination coverage in a range of contexts; and; - have incorporated education with a variety of other activities.; The contribution of individual components to overall effectiveness of these interventions cannot be attributed.
3 Vaccination Requirements for Child Care, School, and College Attendance Recommended Page 15 | Child care, school, and college requirements are laws or policies requiring vaccinations or other documentation of immunity as a condition of attendance. Key Findings; - Vaccination requirements for child care, school, and college attendance are effective in reducing vaccine-preventable disease or improving vaccination coverage.; - Vaccination requirements for child care, school, and college attendance are effective in all relevant populations.; - Differences in effectiveness of state laws based on the law's specific characteristics or its enforcement could not be determined.
4 Communitywide Education Only Insufficient Evidence Page 17 | Communitywide education-only interventions provide information to most or all of a target population in a geographic area. These interventions can also provide information to vaccination providers. Interventions that have additional features (e.g., reminders), are used in combination with other interventions (e.g., multicomponent interventions that include education), or are limited to site-specific efforts in a particular setting (e.g., schools or child care centers) are reviewed elsewhere in this chapter. Key Findings; - Only one qualifying study was identified that assessed the effectiveness of communitywide education-only interventions regarding delivery of vaccinations. That study had limitations in design and conduct and found inconsistent results in different subpopulations.; - No qualifying studies were identified evaluating the effectiveness of communitywide education-only interventions regarding knowledge and attitudes.; Therefore, available studies provide insufficient evidence to assess the effectiveness of communitywide education regarding improving vaccination, knowledge, or attitudes.
5 Clinic-Based Education Only Insufficient Evidence Page 18 | Clinic-based education-only interventions provide information to groups served in a specific medical or public health clinical setting. Interventions that have additional features (e.g., reminders), are used in combination with other interventions (e.g., multicomponent interventions that include education), or are provided in other settings (e.g., schools or child care centers) are reviewed elsewhere in this chapter. Key Findings; - Only one qualifying study evaluating the effectiveness of printed educational materials regarding improving vaccination coverage was identified. That study found small and nonsignificant effects regarding coverage.; - Only two before/after studies were identified that evaluated the effects of vaccination information statements regarding client knowledge or attitude toward vaccination. Those studies demonstrated variable effects regarding knowledge and attitudes.; - No studies were identified evaluating clinic-based educational strategies other than printed educational materials.; Therefore, available studies provide insufficient evidence to assess the effectiveness of clinic-based education-only interventions to improve knowledge, attitudes, or vaccination coverage.
6 Client or Family Incentives Insufficient Evidence Page 20 | Client incentives involve providing financial or other incentives to motivate persons to accept vaccinations. Incentives can be either rewards or penalties. Some interventions with aspects of incentives (e.g., Women, Infants, and Children [WIC] programs and child care, school, and college attendance requirements) are reviewed elsewhere in this chapter. Key Findings; - We identified three qualifying studies, and those studies included four intervention arms.; - Only one intervention arm evaluated use of incentives only; it found a 6% change in coverage.; - The other three intervention arms evaluated incentives and reminders with and without additional interventions; those findings were variable in size and statistical significance.; Therefore, on the basis of the (a) small number of available studies, (b) variability in interventions evaluated, and (c) variability in size and statistical significance of results, insufficient evidence exists to assess the effectiveness of client incentives in improving vaccination coverage and whether incentives provide a marginal benefit when combined with reminders.
7 Client-Held Medical Records Insufficient Evidence Page 21 | Client-held medical records that indicate which vaccinations have been received are provided to members of a target population or their families. Key Findings; - Our search identified four qualifying studies of client-held medical records; one evaluated client-held records only and three evaluated client-held records together with clinic-based education, client reminders, or multiple strategies.; - Effectiveness in improving vaccination coverage was variable in size and statistical significance.; Therefore, on the basis of the (a) small number of studies, (b) limitations in study design and conduct, (c) variability in interventions evaluated, and (d) variability in size and statistical significance of reported results, insufficient evidence exists to assess the effectiveness of client-held medical records in improving vaccination coverage.
Enhancing Access to Vaccination Services
8 Reducing Out-of-Pocket Costs Strongly Recommended Page 25 | Reducing out-of-pocket costs to families for vaccinations or administration of vaccinations can be implemented by paying for vaccinations or administration, providing insurance coverage, or reducing copayments for vaccinations at the point-of-service. Key Findings Reducing out-of-pocket costs improves vaccination coverage -; - in children and adults;; - in a range of settings and populations;; - when applied in varying levels of scale from individual clinical settings to statewide programs, to national efforts; and; - whether used alone or as part of a multicomponent intervention.
9 Expanding Access in Healthcare Settings As part of a multicomponent intervention - Strongly Recommended Alone - Insufficient Evidence Page 27 | Expanding access increases the availability of medical or public health clinical settings in which vaccinations are offered by (a) reducing the distance from the setting to the population; (b) increasing or changing hours during which vaccination services are provided; (c) delivering vaccinations in clinical settings in which they were previously not provided (e.g., emergency departments, inpatient units, or subspecialty clinics); or (d) reducing administrative barriers to obtaining vaccination services within clinics (e.g., developing a "drop-in" clinic or an "express lane" vaccination service). Key Findings As a part of multicomponent interventions, expanding access -; - improves vaccination coverage among children and adults; and; - improves vaccination coverage in a range of contexts.; The contribution of individual components to the overall effectiveness of these interventions cannot be attributed. Evidence is insufficient to assess the effectiveness of expanded access only toward improving vaccination coverage because of the (a) small number of studies, (b) relatively small and statistically variable results, and (c) limitations in study design and execution.
10 Vaccination Programs in WIC Settings Recommended Page 30 | Vaccination programs in WIC settings involve efforts to encourage the vaccination of a low-income target population in this nonmedical setting. At a minimum, vaccination-promoting strategies in WIC require assessment of each child's immunization status and referral of underimmunized children to a healthcare provider. Other services can include education, provision of vaccinations, or incentives to accept vaccinations (e.g., monthly voucher pickup, which requires more frequent WIC visits when children are not up-to-date). Key Findings; - WIC interventions improve vaccination coverage in children whether used alone or as part of a multicomponent intervention.; - All available studies evaluated assessing the immunization status of WIC clients and either providing vaccinations on-site or referring clients elsewhere for vaccination. Some interventions also used monthly voucher pickup or provided free vaccinations.; The contributions of individual components to the overall effectiveness of vaccination interventions in WIC settings cannot be determined.
11 Home Visits Recommended Page 32 | Home visits to promote vaccinations involves providing face-to-face services to clients in their homes. Services can include education, assessment of need, referral, and provision of vaccinations. Home-visiting interventions also can involve telephone or mail reminders. Key Findings; - Home-visiting interventions improve vaccination coverage.; - Most available studies were conducted in socioeconomically disadvantaged populations.; - At least when applied only to improve vaccination coverage, home-visiting interventions can be highly resource-intensive relative to other available options for improving vaccination coverage.
12 Vaccinations Programs in Schools Insufficient Evidence Page 33 | School-based vaccination interventions are intended to improve delivery of vaccinations to school attendees aged approximately 5-18 years. School-based interventions usually include vaccination-related education of students, parents, teachers, and other school staff plus either provision of vaccinations or referral for vaccinations. These interventions can also involve other components (e.g., providing incentives, acquiring written consent from parents or guardians, and administering vaccinations). Vaccination requirements for school attendance are reviewed elsewhere in this chapter. Key Findings; - Only one qualifying study evaluating the effectiveness of school-based vaccination programs was identified.; - No comparative studies evaluating the effectiveness of school-based vaccination programs to improve vaccination coverage were identified.; Therefore, the effectiveness of school-based vaccination programs could not be assessed.
13 Vaccination Programs in Child Care Centers Insufficient Evidence Page 35 | Interventions in child care centers involve efforts to encourage vaccination of children aged <5 years. These interventions require assessment of each child's immunization status at (a) entry into child care, (b) at some point during the child's enrollment, or (c) at periodic intervals throughout the child's enrollment. Vaccination interventions in child care centers can also include education or notification of parents, referral of underimmunized children to healthcare providers, and possibly, provision of vaccinations on-site. Vaccination requirements for entry into child care centers are reviewed elsewhere in this chapter. Key Findings; - Only one study evaluated the effectiveness of vaccination interventions in child care settings, and it was not included in the review because its execution was limited.; Therefore, available studies provide insufficient evidence to assess the effectiveness of vaccination interventions in child care centers.
Provider-Based Interventions
14 Provider Reminder/Recall Strongly Recommended Page 39 | Provider reminder/recall interventions inform those who administer vaccinations that individual clients are due (reminder) or overdue (recall) for specific vaccinations. Techniques by which reminders are delivered - in client charts, by computer, by mail, or other - and content of the reminders can vary. Interventions that incorporate elements of both reminders and standing orders are reviewed with standing orders in this chapter. Key Findings Provider reminders improve vaccination coverage -; - in adults, adolescents, and children;; - whether used alone or as part of a multicomponent intervention;; - across a range of intervention characteristics (e.g., computerized or simple reminders, checklists, or flowcharts); and; - in a range of settings and populations.
15 Assessment and Feedback for Vaccination Providers Strongly Recommended Page 41 | Provider assessment and feedback involves retrospectively evaluating the performance of providers in delivering one or more vaccinations to a client population and giving this information to providers. Assessment and feedback interventions can also involve other activities (e.g., incentives or benchmarking [i.e., comparing performance to a goal or standard]). Key Findings Assessment and feedback improves vaccination coverage -; - in adults and children;; - whether used alone or as part of a multicomponent intervention; and; - across a range of settings and populations.; The specific characteristics of assessment and feedback interventions (e.g., content, intensity, use of incentives, or benchmarking) that contribute most to effectiveness cannot be determined from available data; however, a variety of assessment and feedback interventions have been consistently effective in a wide range of contexts.
16 Standing Orders For adults - Strongly Recommended For children - Insufficient Evidence Page 43 | Standing orders involve interventions in which nonphysician personnel prescribe or deliver vaccinations to client populations by protocol without direct physician involvement at the time of the interaction. Settings in which this occurs include clinics, hospitals, and nursing homes. Dedicated vaccination clinics often operate under standing orders, but we did not consider standing orders in that context as an intervention for the purposes of this chapter. Key Findings Standing orders to vaccinate adults -; - improve vaccination coverage whether used alone or as part of a multicomponent intervention; and; - are effective in such settings as hospitals, clinics, and nursing homes.; Insufficient evidence exists to assess the effectiveness of standing orders in improving delivery of vaccinations to children because only one qualifying study was available. Further, that study had limitations in its design and conduct, and it reported effects regarding vaccination coverage that were not substantially different from zero.
17 Provider Education Only Insufficient Evidence Page 45 | Provider education involves giving information regarding vaccinations to providers to increase their knowledge or change their attitudes. Techniques by which information is delivered can include written materials, videos, lectures, continuing medical education programs, and computerized software. Interventions that have additional features (e.g., provider reminders or assessment and feedback) or that are used in combination with other interventions (e.g., multicomponent interventions that include education) are reviewed elsewhere in this chapter. Key Findings Only four qualifying studies of provider education-only interventions were identified.; - Two studies of low-intensity interventions evaluated the impact of these interventions regarding vaccination coverage. One documented small and nonsignificant impacts regarding coverage; the other found that provider education produced smaller impacts regarding coverage than provider reminder/recall interventions or standing orders.; - Three studies of provider education-only interventions found variable impacts regarding provider knowledge and attitudes. The best-described and most-intensive intervention produced improvements in provider knowledge and attitudes.; Therefore, because of the (a) small number of studies, (b) limitations in design and conduct, and (c) variability in results, we could not assess the effects of provider education only in changing provider knowledge or attitudes or vaccination coverage.

## BACKGROUND

Vaccine-preventable diseases among children, adolescents, and adults represent major continuing causes of morbidity and mortality in the United States. During the last half of the twentieth century, the success of childhood vaccination programs in the United States has led to a >95% decline in most vaccine-preventable diseases of childhood. However, >400,000 cases of illness and >30,000 deaths caused by vaccine-preventable diseases still occur each year (CDC unpublished data,1).

Diphtheria, invasive Haemophilus influenzae type b (Hib) disease, measles, poliomyelitis, rubella, tetanus, mumps, varicella, and pertussis are typically referred to as vaccine-preventable diseases of childhood. Vaccinations primarily indicated for adults include influenza, pneumococcal, and hepatitis B. However, during the 1990s, the distinction between childhood and adult vaccine-preventable diseases became less clear. Many childhood vaccine-preventable infections, including measles and pertussis, are found increasingly among adults (2,3), and hepatitis B vaccinations are now routinely recommended for infants and adolescents. The table on the next page outlines universally recommended (i.e., vaccinations recommended for most or all persons in certain age groups) vaccinations for children, adolescents, and older adults.

In children, >50,000 cases of varicella occur each year, making that disease the most common vaccine-preventable disease among children (4); in adults, influenza, pneumococcal disease, and hepatitis B are all still common vaccine-preventable diseases, with hundreds of thousands of cases occurring each year (5). Mortality attributable to vaccine-preventable diseases is still substantial. Each year, approximately 500 persons in the United States die of childhood vaccine-preventable diseases, and >30,000 adults die of influenza, pneumococcal infections, and hepatitis B (1). Influenza, which accounts for an average of 20,000 deaths/year, is usually the largest killer (5).

The effectiveness of universally recommended vaccinations in preventing disease for adults, adolescents, and children is well established (6,7,8,9,10,11,12,13,14). In addition to protecting individuals - for diseases passed from person to person - vaccination provides population-based (herd) immunity that prevents circulation of infectious agents. In general, uniformly high coverage levels will maximize protection of individuals and the population.

Vaccination coverage levels among U.S. school children exceeds 98% for vaccination with diphtheria-tetanus toxoids and pertussis vaccine (DTP)/pediatric formulation of diphtheria and tetanus toxoids (DT), oral poliovirus vaccine (OPV), measles-containing vaccine, and Hib (15). Vaccination coverage among U.S. children aged 19-35 months exceeds 90% for three or more doses of DTP/DT, three or more doses of OPV, one or more doses of a measles-containing vaccine, and three or more doses of Hib vaccine (16), but is lower for four or more doses of DTP vaccine (81%), three or more doses of hepatitis B vaccine (84%), and varicella vaccine (26%). In addition, certain populations remain at higher risk for underimmunization. Recent data indicate that coverage levels for children aged 2 years remain significantly lower among urban populations as well as among low-income populations (16,17).

Vaccinations recommended for adults and more recently for adolescents are underused. Recent estimates indicate that <60% (18) of adults aged >65 years are vaccinated against influenza and pneumococcal infection. No reliable estimates exist for vaccination coverage levels among adolescents.

Universally Recommended Vaccinations

Population | Vaccination | Dosage
All Young Children | Measles, Mumps, and Rubella | 2 Doses
All Young Children | Diphtheria-Tetanus Toxoid and Pertussis Vaccine | 5 Doses
All Young Children | Poliomyelitis | 4 Doses
All Young Children | Haemophilus influenzae Type B | 3-4 Doses
All Young Children | Hepatitis B | 3 Doses
All Young Children | Rotavirus | 3 Doses Before First Birthday
All Young Children | Varicella | 1 Dose
Previously Unvaccinated or Partially Vaccinated Adolescents | Hepatitis B | 3 Doses, Total
Previously Unvaccinated or Partially Vaccinated Adolescents | Varicella | If No Previous History of Varicella, 1 Dose for Children Aged <12 Years, 2 Doses for Children Aged >13 Years
Previously Unvaccinated or Partially Vaccinated Adolescents | Mumps, Measles, and Rubella | 2 Doses, Total
Previously Unvaccinated or Partially Vaccinated Adolescents | Tetanus-Diphtheria Toxoid | If Not Vaccinated During Previous 5 Years, 1 Combined Booster During Ages 11-16 Years
All Adults | Tetanus-Diphtheria Toxoid | 1 Dose Administered Every 10 Years
All Adults Aged >65 Years | Influenza | 1 Dose Administered Annually
All Adults Aged >65 Years | Pneumococcal | 1 Dose

## CONCEPTUAL APPROACH

An explanation of the methods used to conduct the systematic reviews and arrive at the evidence-based recommendations contained in this chapter is found in Appendix A. Tables and figures summarizing effectiveness findings are in Appendix B. Appendix C contains the evidence tables that support our economic analyses.

An illustration of our logic framework depicts the conceptual approach that we chose during chapter development (Figure). This figure portrays the relationships between a population, environmental and health system determinants, categories of interventions, and outcomes. By displaying our conceptual approach graphically, we are able to (a) indicate intervention options for changing relevant outcomes, (b) indicate categories of related interventions, (c) describe the outcomes that the interventions attempt to influence, and (d) indicate clearly the types of interventions that are included in the chapter and those that are not.

Logic Framework Depicting Conceptual Approach Used In This Chapter

We focused on interventions that are intended to improve routine delivery of universally recommended vaccinations. Moreover, we chose not to address vaccinations with more targeted indications (e.g., those recommended for persons with specific medical conditions such as asthma or vaccinations for travelers). The major outcomes that we considered included attendance in healthcare systems, delivery of vaccinations, and vaccine-preventable disease incidence.

Three categories of interventions were selected -

- increasing community demand for vaccinations,
- enhancing access to vaccination services, and
- provider-based interventions.

The selected interventions within those categories were characterized by (a) the nature of the activities involved; (b) how the activities were delivered; (c) who was targeted (e.g., general population, groups at high risk, or a particular professional group); and (d) the setting in which the intervention was applied (e.g., healthcare setting, nonhealthcare setting, or communitywide setting). We reviewed interventions that were either single-component - using only one activity, or multicomponent - using more than one activity together, to achieve desired outcomes. We also assessed the effectiveness of multicomponent interventions in improving coverage and changing other outcomes whether or not the relative contribution of individual components could be ascribed. We did not address other strategies that reduce exposures to vaccine-preventable diseases (e.g., quarantine or outbreak control) or treatment of vaccine-preventable disease to reduce morbidity and mortality.

We grouped similar interventions together on the basis of their similarity and depth of available literature (i.e., the more literature available, the more subcategories that could be evaluated). Sometimes, we found that our classification or nomenclature was different from that used in the original studies being reviewed. When such a discrepancy occurred, we grouped interventions according to our definitions. By the end of the chapter development process, we had reviewed the evidence of effectiveness of 17 interventions that we felt were likely to have a significant impact or were widely practiced. Time and resource constraints prohibited our evaluating other major categories of interventions.

Some activities that might improve vaccination coverage were not considered to be interventions for the purposes of these reviews. Activities that provide information for public health action (e.g., vaccination registries) provide useful information and might even incorporate or lead to interventions (e.g., client reminder/recall interventions, provider reminder/recall interventions, and assessment and feedback for vaccination providers). However, we considered registries to represent a part of the public health infrastructure rather than being interventions themselves. Similarly, improving vaccines (e.g., developing vaccines that are less likely to cause adverse reactions or increasing numbers of antigens contained in a vaccine, thus reducing the number of injections required) can certainly lead to improvements in vaccination coverage. However, they are primarily done for other reasons (e.g., harm reduction or to allow the administration of more antigens than would otherwise be feasible) and are therefore not considered to be interventions for the purposes of these reviews.

## HEALTHY PEOPLE 2010 GOALS AND OBJECTIVES FOR IMPROVING VACCINATION COVERAGE

Healthy People 2010 (U.S. Department of Health and Human Services, Draft for Public Comment, September 1998) is the prevention agenda for the United States. It identifies the significant preventable threats to health and focuses public and private sector efforts to address those threats. Many of the proposed Healthy People objectives in Chapter 22, "Immunization and Infectious Diseases" include goals related to vaccination and vaccine-preventable disease. This chapter provides information on tested interventions that could help communities and health-care systems reach Healthy People objectives.

2010 Objective
22.1 | Reduce indigenous cases of vaccine-preventable disease.
22.2 | Monitor the national impact of influenza vaccinations on influenza-related hospitalizations and mortality among high-risk populations by annually collecting, analyzing, and reporting data from at least one medical care organization in all nine influenza surveillance regions of the country.
22.5 | Reduce to zero cases per 100,000 hepatitis B rates in persons less than 25 years of age (except perinatal infections).
22.17a | Decrease the incidence of invasive pneumococcal infections to 49 per 100,000 persons less than 5 years of age.
22.17b | Decrease the incidence of invasive penicillin-resistant pneumococcal infections to 6.2 per 100,000 population aged 65 [years] and older.
22.21 | Achieve immunization coverage of at least 90% among children 19-35 months of age.
22.22 | Ensure that all 50 states achieve immunization coverage of at least 90 percent among children 19-35 months of age for [selected antigens].
22.23 | Maintain immunization coverage at 95 percent for children in licensed day care facilities and children in kindergarten through the first grade.
22.24 | Increase to 90 percent the rate of [influenza and pneumococcal] immunization coverage among adults 65 years of age or older; 60 percent for high-risk adults 18-64 years of age.
22.30 | Increase to 90 percent the number of 2-year-old children who receive vaccinations as part of comprehensive primary care.
22.31 | (Developmental) Increase to _-_ percent the number of immunization providers who have systematically measured the immunization coverage levels in their practice population.
22.32 | (Developmental) Increase to _-_ percent the number of children enrolled in a fully functional population-based immunization registry (birth through age 5).

## INFORMATION FROM OTHER ADVISORY GROUPS

### Information Regarding Use of Vaccines

The Guide to Clinical Preventive Services; Systematic Reviews and Evidence-Based Recommendations documents the effectiveness of vaccination in preventing disease among individuals and provides general recommendations for clinical practice regarding vaccinations (14). Recommendations regarding administration of childhood vaccinations are issued regularly by the Advisory Committee on Immunization Practices (ACIP) of the U.S. Department of Health and Human Services (DHHS)/Centers for Disease Control and Prevention (CDC) (11), the American Academy of Pediatrics (AAP) (7), and the American Academy of Family Physicians (AAFP) (6). Since 1995, the AAP, AAFP, and ACIP have collaborated regarding a harmonized childhood vaccination schedule (11). Recommendations regarding the administration of adolescent and adult vaccinations are published by ACIP (12,13), the American College of Physicians (9), Infectious Disease Society of America (9,19), AAFP (6), and the American College of Obstetricians and Gynecologists (8). Vaccination recommendations for adolescents are now coordinated among ACIP, AAP, AAFP, and the American Medical Association.

### Information Regarding Improving Vaccination Coverage

Summaries and recommendations regarding interventions to improve vaccination coverage have been developed by the Canadian Community Health Practice Guidelines Working Group (20,21), ACIP (22,23), and the National Vaccine Advisory Committee (24).

## INTERPRETING AND USING THESE RECOMMENDATIONS

Using information from these systematic reviews is important for choosing interventions, but considering local context is equally important. Local context includes observed problems, community preferences and priorities, and specific interventions that are feasible and appropriate. Choosing strategies that work in general and that are well-matched to local needs and capabilities, and then implementing those interventions well, are vital to improving vaccination coverage at the local level. This section provides guidance for combining the information found in these reviews and recommendations (i.e., strategies that work in general) with local contextual information (i.e., ensuring a good match between interventions and local needs and capabilities).

A starting point for addressing vaccine-preventable disease problems in communities is to assess activities currently being performed, current levels of vaccination coverage, and information regarding disease rates. These should be compared with such relevant goals as those in Healthy People 2000 (25), Healthy People 2010 (U.S. Department of Health and Human Services, Draft for Public Comment, September 1998), as well as additional goals developed locally. In addition to assessing overall progress toward vaccination goals, health planners should also consider whether special attention is warranted for population groups at high risk. In general, the lower the vaccination coverages and the higher the burden of vaccine-preventable diseases in a population or subgroup, the greater the need to improve coverage. For example, all vaccine-preventable diseases except tetanus are spread by person-to-person contact. Urban, low-socioeconomic-status populations are particularly vulnerable when immunization rates are low. Therefore, improving coverage among impoverished persons in urban communities should be a priority.

If improvement in vaccination coverage for a population or subgroup is warranted, causes of underimmunization should be assessed and interventions chosen that address local problems. Even generally effective strategies are unlikely to achieve objectives if they are poorly matched to local needs. As discussed previously in this chapter, interventions are grouped into three general categories. Each of those categories includes several specific interventions. This categorization is intended to facilitate the ability of users to match interventions to problems. For example,

- In the United States, most people accept the need for vaccinations and are seen periodically in healthcare settings, but unfortunately, providers often miss opportunities to vaccinate. Provider-based interventions are good choices for addressing those missed opportunities.
- Increasing recognition, acceptance, and use of new vaccines by providers is a problem that will be confronted increasingly. Provider-based interventions are also good choices for increasing the use of new vaccines.
- If an undervaccinated population had few or no contacts with the healthcare system, an intervention to increase access might be appropriate.
- If lack of knowledge among clients regarding need for vaccination contributes to low coverage, a strategy to increase demand could be useful.

Therefore, once a general strategy for addressing a local problem is selected, the recommendations in this chapter can be used in conjunction with local experience to help select appropriate interventions. Recommendations and effectiveness data can be used to assess the extent to which interventions have been found to consistently improve vaccination coverage. In general, the use of strongly recommended and recommended interventions should be increased. The section regarding applicability can be used to assess the extent to which the interventions reviewed might match a particular local situation. At present, available economic information is limited in both quantity and quality. Although limited, economic information could be useful in identifying interventions that meet public health goals more efficiently than other available options for reaching the same goals. Reviews and recommendations provided in this guide need to be considered along with such local information as resource availability, administrative structures, economic, social, and regulatory environment of organizations and practitioners.

Some circumstances could lead to using two or more interventions together. Most importantly, a single intervention might not address multiple problems contributing to low vaccination rates. For example, if both lack of demand for vaccinations among clients and missed opportunities to provide vaccinations by providers were occurring together, interventions to address both of these might be useful. Other circumstances (e.g., particularly low vaccination coverage or high levels of community interest) might also support selection of multicomponent interventions.

The available scientific data provided in the chapter do not provide clear answers regarding how and when activities should be combined. However, data from the chapter could be useful in identifying activities that are individually effective and activities that have been previously used together successfully.

## Increasing Community Demand for Vaccinations

Interventions that increase community demand for vaccinations are designed to increase knowledge regarding and demand for vaccination services. Interventions that increase community demand for vaccinations reviewed in this chapter include client reminder/recall, multicomponent interventions that include education, vaccination requirements for child care, school, and college attendance, communitywide education only, client or family incentives, and client-held medical records.

### 1 Client Reminder/Recall

Client reminder/recall interventions involve reminding members of a target population that vaccinations are due (reminders) or late (recall). Reminders differ in content and are delivered by various methods - telephone, letter, postcard, or other. Interventions that incorporate aspects of both client reminder/recall and home visits are reviewed under home-visiting interventions.

- in children and adults;
- in a range of settings and populations;
- when applied at different levels of scale from individual practice settings to entire communities;
- across a range of intervention characteristics (e.g., reminder or recall; content; theoretical basis; and method of delivery); and
- whether used alone or as part of a multicomponent intervention.

#### Background

Reminders and recalls allow clients to know when vaccinations are due or overdue, as well as when to contact their vaccination provider to determine if vaccinations are needed. Reminders or recalls can be mailed or communicated by telephone; an autodialer can be used to expedite telephone reminders. Client reminders can be either specific (i.e, certain vaccinations are due on a specific date) or general.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 60 studies regarding the effectiveness of client reminder/recall interventions (26-85). Nine additional papers provided more information regarding an already included study (86-94). A total of 18 studies had limited execution (26,27,34,51,54,56,60,62,69,70,75, 81,85) or least-suitable designs (35,44,53,58,73) and were therefore not included in the review. Details of the 42 qualifying studies are provided in Appendix B.

The qualifying studies reported on 34 intervention arms that evaluated reminders or recalls used alone and 25 intervention arms evaluating multicomponent interventions that included reminders or recalls. Multicomponent interventions also included expanded access (31,32,33,36,37,57,63,66,72,84), provider reminders (36,38,42,43,52,72,74), clinic-based education (28,29,31,33,36,42), provider education (30,31,32,33,36,63), reducing out-of-pocket costs (28,30,32,66,71,76), provider assessment and feedback (36,42,47), client incentives (33,66,84), communitywide education (30,32,38), standing orders (63,72), Women, Infants, and Children (WIC) program interventions (32), home visits (33), and client-held medical records (28).

Two qualifying studies (78,84) provided data that could not be expressed as a percentage point change in coverage. The remaining studies provided data regarding 31 single-component and 23 multicomponent intervention arms. Overall, these studies documented a median change of 12% (range, -8%-47%). Studies that evaluated client reminder/recall-only interventions documented a median change of 8% (range, -7%-31%). Studies that evaluated client reminder/recall as part of a multicomponent intervention documented a median change of 16% (range, -8%-47%).

Most qualifying studies evaluated reminders, although some evaluated both reminders and recalls (39) or recalls only (61,82). Studies evaluated both telephone (39,40,45,52,64,80) and mailed (29,40,41,45,46,47,48,49,50,55,57,61,64,65,66,67,68,71,76,77,78,82,83,84) reminders. Mailed reminders included both letters and postcards. Two studies (45,64) directly compared mailed reminders with telephone reminders and did not find a difference regarding effectiveness between them. Six studies evaluated intensity of reminders (e.g., general to more specific, generic to personalized, and signed by physician as well as greater versus lesser numbers of reminders) (49,50,59,66,83,84), and five of the six studies found greater increases in coverage with more-intensive reminders. No studies were found evaluating reminders delivered by computers (e.g., by e-mail).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccinations. Studies have included adults (30,36,37,41,42,43,45,46,47,49,52,55,57,59,63,64,65,66,67,68,71,72,74,76,77,83) and children (29,31,32,33,38,39,40, 48,61,78,80,82,84). Adolescents have been studied in mother-infant pairs (28) but have not been studied regarding their own vaccinations. Studies have included white (31,55,84), black (28,29,39,41,43,48,74), and Hispanic (29,31,32,40) persons, urban (28,36,39,41,45,48,49,57,67), suburban (41,45,46), and rural (45,46,50,52) populations, and both poor (28,31,32,33,39,40,43,46,48,52,65,74) and nonpoor (31,46,55,61) persons. Studies have been done in a range of settings including academic clinical settings (28,29,40,43,45,48,59,64,66,77), public health settings (31,80,82,83), managed care (33,61,63,68), private practice (36,46,47,52), pharmacies (55), and communitywide settings (30,38,50,78). Studies are available to assess the effectiveness of these interventions to improve vaccination delivery of measles, mumps, and rubella (MMR) (32,33,38,39,40,61), DTP (29,31,32,33,39,40,48,80,82), OPV (29,31,32,33,39,40), Hib (33,39,40), influenza (30,36,37,41,42,43,45,46,47,49,50,55,57, 59,63,64,65,66,67,68,71,72,76,79,83), pneumococcal (43,77), and adult formulation of diphtheria and tetanus toxoids (Td) (43,52,64). No studies were found evaluating client reminder/recall to encourage adolescent vaccinations or to improve delivery of hepatitis B vaccinations.

##### Evidence of Other Positive or Negative Effects

No other positive or negative effects of client reminder/recall interventions were sought in this review.

##### Economic Evidence

Our search identified 11 economic evaluations of client reminder/recall interventions (27,46,52,61,65,71,93,95,96,97,98). One additional paper provided more information regarding an already included study (64). Details of the studies are provided in Appendix C. A total of 9 studies provided 12 cost-effectiveness ratios for single-component reminder/recall interventions and 3 cost-effectiveness ratios for multicomponent interventions that include reminder/recall. Adjusted cost-effectiveness ratios for single-component interventions based on those studies ranged from $3/additional vaccination to $46/additional vaccination (median, $9). Adjusted cost-effectiveness ratios for multicomponent interventions were $4/additional vaccination for a combination of client and provider reminders (52); $51/additional vaccination for a combination of reminders and a lottery-type incentive (65); and $43/additional vaccination for a combination of mailed reminders and free vaccinations (71).

Adjusted average costs based on 2 available studies varied from $0.65 to $5.75/child. The lower cost is an underestimate because the cost of the in-kind contribution of volunteer time was not included. The upper cost might be an overestimate because it includes costs of clinical time to provide vaccinations.

#### Barriers to Intervention Implementation

Barriers to implementing reminder/recall interventions might include lack of information infrastructure and administrative burden on providers or systems.

#### Recommendation

According to the Guide's rules of evidence, client reminder/recall is strongly recommended on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

### 2 Multicomponent Interventions That Include Education

Multicomponent interventions that include education provide knowledge to target populations and in some instances, to vaccination providers, and use at least one other activity to improve vaccination coverage.

- improve vaccination coverage among children and adults;
- improve vaccination coverage in communitywide and clinic-based settings;
- improve vaccination coverage in a range of contexts; and
- have incorporated education with a variety of other activities.

#### Background

Multicomponent interventions that include education address health concerns and barriers to vaccination in an integrated way. Multicomponent interventions that include education are based on the premise that prerequisites to health include the physical, social, and political environment in which health risks occur. These interventions make community members aware of vaccination services available to them, the utility and relevance of these services, and information that will help to take advantage of these services. These interventions also incorporate a variety of associated strategies to improve vaccination.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 34 studies regarding the effectiveness of multicomponent interventions that include education (26-38,99-120). Three additional papers provided more information regarding an already included study (86,87,89). Seventeen studies had limited execution and were therefore not included in the review (26,27,34,99-105,109,110,112,113,115,116,119). Details of the 17 qualifying studies are provided in Appendix B. All qualifying studies evaluated interventions that included community or client education. The interventions also included client reminders (28,29,30,31,32,33,35,36,38), provider education (30,31,32,33,36,108), expanded hours or access in clinical settings (31,32,33,36,107,111), provider reminders (28,36,37,38,106,114), reducing out-of-pocket costs (28,30,32,108), client-held vaccination records (28,117), WIC interventions (32), medical and psychosocial assessments (107), nutrition services (107), and home visits (33). Fifteen studies (28,29,30,31,32,33,35,36,37,38,106,107,108,117,118) that reported measures of vaccination coverage found changes in vaccination coverages ranging from -4% to 29% (median, 16%) in follow-up times of as much as 5 years. Positive effects were found both in clinical and community settings (median, 16%, range, -4%-25% versus median, 12%, range, 5%-29%, respectively). Available data do not allow attribution of the portion of the overall effect of the interventions to individual components but suggest that combined interventions increase vaccination coverages.

Any of several reasons could explain the fact that multicomponent interventions that include education seemed effective in improving vaccination coverages, whereas some components (e.g., communitywide education [section 4], clinic-based education [section 5], and expanded clinic hours or access [section 9]) by themselves demonstrate less-convincing evidence of effectiveness. Possibly, this reflects -

- more studies of multicomponent interventions;
- greater intensity (and thus greater effectiveness) of multicomponent interventions;
- synergy between components of multicomponent interventions (i.e., the whole is more effective than the sum of the parts); or
- education only might not cause large increases in acceptance of vaccinations, but could facilitate implementation of other components.

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccinations. Studies have included adults (30,36,37,106,108,114,117,118) and children (28,29,31,32,33,35,38,107). Adolescents have been studied in mother-infant pairs (28,107) but have not been studied regarding their own vaccinations. Studies have been performed in populations including white (31,117,108,118), black (28,29), and Hispanic (29,31,32,107,117) persons and in populations including poor (28,31,32,33,114) and nonpoor (31,107) persons. Studies in clinical settings come primarily from academic clinical organizations (28,29,106,107,114,117,118) but have also been done in private physician's offices (36), public health clinics (31), and managed care (33). Studies are available that demonstrate improvements in vaccination delivery of influenza (30,36,37, 108,117,118), pneumococcal (106,117,118), Td (114,), DTP and OPV (29,31,32,33), MMR (32,33,38,111), and Hib (33). No studies were found evaluating multicomponent educational strategies to encourage adolescent vaccinations or to improve delivery of hepatitis B vaccinations.

##### Evidence of Other Positive or Negative Effects

Several qualifying studies that assessed nonvaccination outcomes (e.g., improved delivery of other preventive or clinical care) (28,107,114,117) found improvements in some nonvaccination outcomes. Other positive or negative effects of multicomponent educational interventions are discussed under the individual components.

##### Economic Evidence

Our search identified two economic evaluations of multicomponent interventions that include education (109,120). Details of the studies are provided in Appendix C. No studies of cost-effectiveness were available. One study evaluated the costs of an intervention that included assembling a community task force, undertaking a media campaign, and implementing a school-based program that assessed students' immunization status and delivered vaccinations (109). The adjusted estimate of average program costs based on that study is $23/child vaccinated. Another study estimated the costs of an intervention that included expanded access to vaccination services, multiple education and health promotion activities, and possibly, provider assessment and feedback (120). The adjusted estimate of average program costs based on that study is $7.65/vaccination delivered. Children in the first study could have received more than one vaccination, so the estimates might be more similar than they appear.

#### Barriers to Intervention Implementation

Potential barriers to implementing multicomponent educational strategies could include difficulties in coordinating strategies between varying programs and administrative systems.

#### Recommendation

According to the Guide's rules of evidence, multicomponent interventions that include education are strongly recommended on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

### 3 Vaccination Requirements for Child Care, School, and College Attendance

Child care, school, and college requirements are laws or policies requiring vaccinations or other documentation of immunity as a condition of attendance.

- Vaccination requirements for child care, school, and college attendance are effective in reducing vaccine-preventable disease or improving vaccination coverage.
- Vaccination requirements for child care, school, and college attendance are effective in all relevant populations.
- Differences in effectiveness of state laws based on the law's specific characteristics or its enforcement could not be determined.

#### Background

Enactment and enforcement of state immunization laws during the 1970s-80s led to >95% of school-age children now being appropriately vaccinated with recommended doses of vaccine. Immunization requirements for child care and college attendance and their enforcement are more recent and vary greatly among states.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 10 studies regarding the effectiveness of vaccination requirements for child care, school, or college attendance (121-130). An additional paper provided more information regarding an already qualifying study (131). One study had limited execution and was not included in the review (130). Details of the nine qualifying studies are provided in Appendix B. Six of the available studies found positive effects regarding disease rates (121,123,125,127,128,129). Three nationwide cross-sectional or before/after studies found that states with immunization requirements for school-aged children had lower incidence of measles (125,129) and mumps (128). Additionally, officials in areas with low incidence of measles were more likely to enforce school laws by excluding noncompliant children from attendance (125). A cross-sectional study from New Jersey found that children covered by a law requiring mumps vaccination were much less likely to have mumps during an outbreak than other children (123). A time-series study from New York found that requiring Hib vaccinations for attendance in child care (without any enforcement) resulted in declines in Hib incidence among child care attendees that exceeded declines for New York as a whole (127). A retrospective cohort study found that state laws requiring prematriculation measles vaccinations resulted in lower risk for measles outbreaks after controlling for other variables (121).

The three studies that looked at vaccination coverage as an outcome found a median change of 15% (range, 5%-35%). A before/after study in Ontario, Canada (122), found that immunization requirements for all school attendees aged 5-17 years produced coverage differences ranging from 3%-9% by antigen (equally weighted average = 5%) from a relatively high baseline coverage of 87%. A time-series study (126) over a 7-year period (1979-86) following enactment of school laws in California in 1977 and enforcement in 1986 documented that vaccination coverage among children aged 5-6 years increased approximately 15% from a baseline coverage of approximately 75%. A cross-sectional study (123) in New Jersey found that children aged <7 years required by a school law to be vaccinated against mumps were more likely to have "documented immunity" (either vaccination or physician documented history of disease) than children not covered by the law (96% versus 61%, respectively). A time-series study (124) that evaluated the effect of a school law for rubella regarding immunity to rubella found an initial improvement in immunity that was not sustained several years later.

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccinations. The majority of the available studies evaluated school laws (122,123,124,125,126,128,129), but other studies also evaluated vaccination requirements for child care (127) and college attendance (121). Generally, available studies did not describe the study populations in detail. However, many of these studies included all 50 states (125,128,129). Other studies used representative samples of U.S. 2- and 4-year colleges (121); statewide data from New York (127) or California (126); or provincial data from Ontario, Canada (122). The evidence of effectiveness should apply to most children and young adults in the United States.

Studies are available that assess the effectiveness of these interventions in improving delivery of MMR or another measles-containing vaccinations (122,126) and in reducing occurrence of measles (125,129) and mumps (123,128); in improving coverage with DT or DTP and OPV (122,126); and in reducing incidence of Hib (127). No studies were found evaluating the effectiveness of these interventions in improving delivery of hepatitis B vaccinations.

##### Evidence of Other Positive or Negative Effects

No other positive or negative effects of vaccination requirements for child care, school, or college attendance were sought in this review.

##### Economic Evidence

No economic evaluations of vaccination requirements for child care, school, and college attendance were identified.

#### Barriers to Intervention Implementation

Potential barriers to implementation of vaccination requirements for child care, school, and college attendance include administrative burden, difficulty coordinating various programs, and difficulty passing legislation.

#### Recommendation

According to the Guide's rules of evidence, vaccination requirements for child care, school, and college attendance are recommended on the basis of sufficient scientific evidence that such requirements improve coverage and immunity or they reduce rates of disease.

### 4 Communitywide Education Only

Communitywide education-only interventions provide information to most or all of a target population in a geographic area. These interventions can also provide information to vaccination providers. Interventions that have additional features (e.g., reminders), are used in combination with other interventions (e.g., multicomponent interventions that include education), or are limited to site-specific efforts in a particular setting (e.g., schools or child care centers) are reviewed elsewhere in this chapter.

- Only one qualifying study was identified that assessed the effectiveness of communitywide education-only interventions regarding delivery of vaccinations. That study had limitations in design and conduct and found inconsistent results in different subpopulations.
- No qualifying studies were identified evaluating the effectiveness of communitywide education-only interventions regarding knowledge and attitudes.

#### Background

Communitywide education is intended to improve the availability of information regarding vaccinations and increase knowledge, thereby changing behavior. Educational messages are delivered by various methods (e.g., mail, radio, newspapers, television, and posters). Communitywide education can result in increases in vaccination coverage by increasing acceptance and demand for vaccinations among clients.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified six studies regarding the effectiveness of communitywide education-only interventions (38,56,75,132,133,134). Of these, five (56,75,132,133,134) had limited execution and were therefore not included in this review. The qualifying time-series study, conducted with children, found some improvements in the number of measles vaccinations delivered among those aged 6 years but not among those aged 14-18 months coincident with a mass-media campaign. The study did not provide substantial information regarding content or intensity of the intervention. Details of the qualifying study are provided in Appendix B. No studies were identified evaluating the effect of communitywide education-only interventions regarding knowledge or attitudes.

##### Evidence of Other Positive or Negative Effects

No studies evaluating other positive or negative effects of communitywide education-only interventions were sought.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of communitywide education-only interventions regarding improving knowledge or attitudes regarding vaccinations or in improving delivery of vaccinations. However, communitywide education is a central component of many effective interventions. Until more and better information becomes available, communities might choose to make decisions regarding use of communitywide education-only interventions on grounds other than available studies.

### 5 Clinic-Based Education Only

Clinic-based education-only interventions provide information to groups served in a specific medical or public health clinical setting. Interventions that have additional features (e.g., reminders), are used in combination with other interventions (e.g., multicomponent interventions that include education), or are provided in other settings (e.g., schools or child care centers) are reviewed elsewhere in this chapter.

- Only one qualifying study evaluating the effectiveness of printed educational materials regarding improving vaccination coverage was identified. That study found small and nonsignificant effects regarding coverage.
- Only two before/after studies were identified that evaluated the effects of vaccination information statements regarding client knowledge or attitude toward vaccination. Those studies demonstrated variable effects regarding knowledge and attitudes.
- No studies were identified evaluating clinic-based educational strategies other than printed educational materials.

#### Background

Clinic-based education-only interventions might include informational brochures (e.g., "Vaccine Information Statements"), videotapes, or posters that could enable the client to take advantage of available services in the clinic. "Vaccine Information Statements" are commonly used standardized informational statements that are available to all providers of vaccinations and are distributed to clients both to provide information and obtain consent for vaccination.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified five studies regarding the effectiveness of clinic-based education-only interventions (118,135,136,137,138). Of these, two (136,137) had limited execution and were, therefore, not included in the review. Details regarding the three qualifying studies are provided in Appendix B. One randomized trial (118) comparing a combination of printed client educational materials and provider education with provider education only found nonsignificant increases in vaccination coverage of 3% for influenza (baseline, 23%) and 2% for pneumococcal (baseline, 3%) vaccines. Two before/after studies evaluated the effect of "Vaccine Information Statements" regarding parental knowledge and attitudes. One (135) found a significant increase in client knowledge regarding vaccines and desire to have their child vaccinated; the other study (138) found no statistically significant effect regarding parental beliefs.

##### Evidence of Other Positive or Negative Effects

No information regarding other positive or negative effects was sought in this review.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of clinic-based education-only interventions regarding improving vaccination coverage. Until more and better information becomes available, communities might choose to make decisions regarding clinic-based education-only interventions on grounds other than available studies.

### 6 Client or Family Incentives

Client incentives involve providing financial or other incentives to motivate persons to accept vaccinations. Incentives can be either rewards or penalties. Some interventions with aspects of incentives (e.g., WIC programs and child care, school, and college attendance requirements) are reviewed elsewhere in this chapter.

- We identified three qualifying studies, and those studies included four intervention arms.
- Only one intervention arm evaluated using incentives only; it found a 6% change in coverage.
- The other three intervention arms evaluated incentives and reminders with and without additional interventions; those findings were variable in size and statistical significance.

#### Background

Client incentives are based on the assumption that clients will be motivated to seek vaccinations for themselves or their children if they receive rewards (e.g., baby toys, money, or discount coupons for retailers) or to avoid penalties (e.g., being excluded from participating in a program).

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified three studies regarding the effectiveness of incentives (33,65,84). All three of those studies were admissible for inclusion in the review, and details regarding those studies are provided in Appendix B. One additional paper provided more information regarding an already included study (89).

The qualifying studies reported on one intervention arm that evaluated using incentives only and three intervention arms that evaluated incentives used with reminders with or without other interventions. One randomized controlled trial (65) was conducted among adults in a community health center. That study evaluated the effectiveness of a lottery for a $50 gift certificate for groceries offered alone or combined with mailed client reminders to improve acceptance of influenza vaccination. The study found that changes for influenza were 9% when the incentive was used alone and 6% (nonsignificant) when combined with reminders; baseline coverage was 20%. A group randomized trial (84), which was conducted in a public health center among children, evaluated a lottery for $25-$100 cash prizes together with mailed client reminders. Change in delivery of at least 1 antigen was 18% during the study period. (This could not be converted to a percentage point change). A retrospective cohort study (33) among parents of children in a Medicaid managed care group gave $10 gift certificates when vaccinations were obtained in conjunction with a multicomponent strategy that included provider and parent reminders, home visiting, transportation assistance, and provider education. Differences in coverage with DPT, OPV, MMR, and Hib at age 35 months was 2% (nonsignificant); baseline coverage was 37%. No studies of positive incentives other than lottery-type incentives or gift certificates, nor studies of negative incentives, were identified.

##### Evidence of Other Positive or Negative Effects

No information regarding other positive or negative effects was sought in this review.

#### Barriers to Intervention Implementation

Potential barriers to incentives include ethical concerns regarding the potential for coerciveness of these interventions.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of client or family incentives for improving vaccination coverage. Until more and better information becomes available, communities might choose to make decisions regarding incentives on grounds other than available studies.

### 7 Client-Held Medical Records

Client-held medical records that indicate which vaccinations have been received are provided to members of a target population or their families.

- Our search identified four qualifying studies of client-held medical records; one evaluated client-held records only and three evaluated client-held records together with clinic-based education, client reminders, or multiple strategies.
- Effectiveness in improving vaccination coverage was variable in size and statistical significance.

#### Background

Client-held medical records can be used to assess a client's immunization status in medical and other settings and can improve a client's awareness of vaccinations needed or due. State and local health departments and providers have encouraged use of client-held medical records to varying degrees. Client-held medical records could result in improvements in vaccination coverage by (a) increasing client knowledge regarding and demand for vaccinations, (b) reducing missed opportunities to vaccinate in healthcare settings, or (c) a combination of the two.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified eight studies regarding the effectiveness of client-held medical records (28,105,117,139,140,141,142,143). Of these, four had limited execution and were not included in the review (105,139,141,142). Details regarding the four qualifying studies are provided in Appendix B. One of the studies compared the combination of a client-held record and a provider reminder with provider reminders only (143). Other studies evaluated client-held records in conjunction with clinic-based education (117), client reminders (140), or multiple strategies (28). One study (140) reported that "coverages were >45% in both groups" after the intervention and that differences between the groups were not significant. However, that study did not present data that could be expressed as a percentage point change in coverage. The other three studies reported percentage point changes in coverage ranging from 5% to 15%; some findings reached a level of statistical significance but others did not.

##### Evidence of Other Positive or Negative Effects

All qualifying studies found increases in the use of some other preventive or clinical services. No information regarding other positive or negative effects were sought in this review.

#### Barriers to Intervention Implementation

A potential barrier to the use of client-held medical records includes a possible burden placed on providers. One provider survey found that although 80% of providers surveyed reported positive or very positive overall reactions to a "health diary," 17% of providers believed that such records negatively affected client flow (117).

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of client-held medical records in improving vaccination coverage. Until more and better information becomes available, community health planners might choose to make decisions regarding this intervention on grounds other than available studies.

### Research Issues for Increasing Community Demand for Vaccinations

#### Effectiveness

The effectiveness of recommended and strongly recommended interventions in this section (multicomponent interventions that include education; client reminder/recall; and vaccination requirements for child care, school, and college attendance) is established. However, research questions regarding the effectiveness of these interventions remain.

- What particular characteristics of interventions to increase community demand for vaccinations contribute to increased or lessened effectiveness?
  - - How do content, specificity, method of delivery, and frequency of delivery of reminder/recall contribute to effectiveness?
  - - How do cultural characteristics of clients contribute to increased or lessened effectiveness of different interventions?
  - - What is the relative effectiveness of reminder and recall systems?
  - - What are the least- and most-effective combinations of services in multicomponent interventions?
  - - How does the effectiveness of vaccination requirements for child care, school, and college attendance vary by specific requirements of legislation and vigorousness of enforcement?
- Do registries provide a functional backbone for effective interventions, including education or client reminder/recall?

Because the effectiveness of communitywide education-only interventions, clinic-based education-only interventions, client or family incentives, and client-held medical records regarding improving vaccination coverage has not been established, basic research questions remain.

- Are these interventions effective in improving vaccination coverage?
- Do these interventions promote positive or negative attitudes toward vaccination among target populations?
- What attributes of clinic-based or communitywide educational programs - medium, message, intensity - contribute to effectiveness or lack thereof?
- What attributes of incentives (e.g., type or amount) contribute to effectiveness or lack thereof?
- Do multiple competing prevention messages act in ways that are synergistic or interfering?
- Do client-held medical records reduce missed opportunities for vaccination?

#### Applicability

Each recommended and strongly recommended intervention should be applicable in most relevant target populations and settings. However, possible differences in the effectiveness of each intervention for specific subgroups of the population could not be determined. Several questions regarding the applicability of these interventions in settings and populations other than those studied remain.

- Are these interventions effective in improving vaccination coverage in adolescents?
- Do meaningful differences exist in effectiveness of these interventions based on the level of scale at which they are delivered (i.e., communitywide systems from a registry versus managed care-based systems versus practice-based systems)?

#### Other Positive or Negative Effects

With the exception of some discussion of improved use of other clinical and preventive care, the studies included in this review did not report on other positive or negative effects of these interventions. Therefore, research regarding the following questions would be useful:

- Do interventions implemented at the community level (e.g., communitywide education-only interventions or multicomponent interventions that include education) result in positive outcomes other than improved vaccination coverage (e.g., community empowerment)?
- Do clinic-based interventions to increase client demand for vaccinations interfere with office flow or efficiency, and if so, how can this effect be minimized?
- Do child care, school, and college vaccination requirements interfere with the other activities of the settings, and if so, how can that effect be minimized?
- Do these interventions result in other positive changes in disease prevention or healthcare as well as improving vaccination coverage?

#### Economic Evaluations

In general, available economic information was sparse; therefore, considerable research is warranted regarding the following questions:

- What are the costs of these interventions?
- How do the costs per additional child vaccinated compare with other interventions to improve vaccination coverage?
- Can strategies that are designed to improve vaccination coverage and other outcomes concurrently improve cost-effectiveness of these strategies?
- How do specific characteristics of these interventions contribute to economic efficiency?
  - - What are the relative economic consequences of reminder and recall systems?
  - - What characteristics of reminders or recall (e.g., frequency, content, or method of delivery) are the most cost-effective?
  - - What combinations of components in multicomponent interventions are most cost-effective?
- What is the cost-benefit or cost-utility of these interventions?

#### Barriers

- How can these interventions be implemented with minimal administrative burden placed on providers or systems?
- Do communitywide registries reduce barriers to use or increase use of these interventions?

## Enhancing Access to Vaccination Services

Interventions that enhance access to vaccination services are designed to reduce the cost or to increase the convenience of obtaining vaccinations. Interventions that enhance access to vaccination services reviewed in this chapter include reducing out-of-pocket costs, expanding access in health-care settings, and vaccination interventions in nonmedical settings, including vaccination programs in WIC settings, home visits, vaccination programs in schools, and vaccination programs in child care centers.

### 8 Reducing Out-of-Pocket Costs

Reducing out-of-pocket costs to families for vaccinations or administration of vaccinations can be implemented by paying for vaccinations or administration, providing insurance coverage, or reducing copayments for vaccinations at the point-of-service.

- in children and adults;
- in a range of settings and populations;
- when applied in varying levels of scale from individual clinical settings to statewide programs, to national efforts; and
- whether used alone or as part of a multicomponent intervention.

#### Background

The out-of-pocket costs of vaccination are commonly cited by clients and providers as a barrier to obtaining vaccinations (144). Many interventions have been used by the U.S. government (e.g., the Vaccines For Children Program), state governments (e.g., provision of free vaccinations), and managed care organizations (e.g., reducing copays) to reduce this barrier. Reducing out-of-pocket costs can result in increases in vaccination coverage either by improving availability of vaccinations or increasing demand for vaccinations.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 26 studies regarding the effectiveness of reducing out-of-pocket costs (28,30,35,56,67,71,76,101,108,110,116,145,146,147,148,149,150,151,152,153,154,155,156,157,158,159). Two additional papers provided more information regarding an already included study (160,161). Seven studies had limited execution and were therefore not included in the review (56,101,110,116,146,152,155). Details of the 19 qualifying studies are provided in Appendix B. Of the qualifying studies, 14 evaluated the effectiveness of reducing out-of-pocket costs regarding improving vaccination outcomes (28,30,35,67,71,76,108,147,148,149,150,153,156,158); four evaluated the effectiveness of these interventions regarding improving provider-reported likelihood of referring clients elsewhere for vaccinations (145,151,154,159), and one evaluated both vaccination and referrals (157).

Of the studies evaluating vaccination outcomes, seven evaluated reducing out-of-pocket costs as a single-component intervention, and eight evaluated multicomponent interventions that included reducing out-of-pocket costs. Multicomponent interventions included client reminder/recall (28,30,67,71,76), communitywide education (30,108), expanding access in healthcare settings (67,156), provider education (30,108), clinic-based education (28), client-held medical records (28), WIC interventions (148), and provider reminder/recall (28).

Two studies evaluating the effects regarding coverage of single-component interventions suggested increased (150) or earlier (158) vaccination, but did not present results that could be expressed as a percentage point change in coverage. The remaining 13 studies reported on 15 intervention arms that found changes in coverage ranging from -8% to 47% (median, 15%). The five studies of single-component interventions that could be expressed as percentage point changes in coverage reported on six intervention arms that found changes in coverage ranging from -1% to 29% (median, 10%). Eight studies evaluating the effects of multicomponent interventions regarding coverage reported on nine intervention arms and found changes in coverage from -8% to 47% (median, 16%) (28,30,67,71,76,108,148,156).

Five provider surveys (145,151,154,157,159) with fair or good execution found that providers reported being more likely to refer children with less public or private insurance coverage to other sites for vaccination. Two of these studies (154,159) were nationally representative surveys of pediatricians and family physicians.

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions of different settings, populations, and vaccines. Studies have included children (35,147,148,153,156,157,158) and adults (30,67,71,76,108,149,150). Adolescents have been studied in mother-infant pairs (28) but not regarding their own vaccinations. Studies have been performed in urban (28,67,108,148,156) and rural (30,149) settings, and in populations with low (28,148,153,156) and mixed (150,158) socioeconomic status. Settings in which reduced cost vaccinations were provided included hospitals (28,149), clinics (147,149), private offices (157,158), WIC sites (148), and emergency departments (156).

##### Economic Evidence

Our search identified one economic evaluation of interventions offering free or discounted vaccinations (71). Details of this study are provided in Appendix C. This study evaluated the cost-effectiveness ratio of a multicomponent intervention offering mailed reminders and free vaccine to encourage influenza vaccination. The adjusted cost-effectiveness ratio of this intervention compared with no intervention on the basis of this study was $43/additional vaccination.

##### Evidence of Other Positive or Negative Effects

In regard to the question of whether reducing out-of-pocket costs negatively affects vaccine research and development, our search did not identify any studies related to that issue. No other positive or negative effects of this intervention were sought in this review.

#### Barriers to Intervention Implementation

Potential barriers to implementation of reducing out-of-pocket costs include fragmentation of payment mechanisms.

#### Recommendation

According to the Guide's rules of evidence, reducing out-of-pocket costs for vaccinations is strongly recommended on the basis of strong scientific evidence of its effectiveness in improving vaccination coverage.

### 9 Expanding Access in Healthcare Settings

Expanding access increases the availability of medical or public health clinical settings in which vaccinations are offered by (a) reducing the distance from the setting to the population; (b) increasing or changing hours during which vaccination services are provided; (c) delivering vaccinations in clinical settings in which they were previously not provided (e.g., emergency departments, inpatient units, or subspecialty clinics); or (d) reducing administrative barriers to obtaining vaccination services within clinics (e.g., developing a "drop-in" clinic or an "express lane" vaccination service).

- improves vaccination coverage among children and adults; and
- improves vaccination coverage in a range of contexts.

#### Background

Surveys of client attitudes and behaviors have identified inconvenience of obtaining vaccinations as an major barrier toward improving vaccination rates in children (144). This factor might be important for disadvantaged, low-income families, many of whom have large families and little financial support for child care or transportation.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 25 studies regarding the effectiveness of expanded access (27,31,32,33,36,37,57,63,67,72,73,84,101,103,107,110,111,116,119,139,146,156,162,163,164). Four additional papers provided more information regarding an already included study (86,88,89,91). Nine studies were not included in the review because of limited execution (27,101,103,110,116,119,139,146,163). Details regarding the 16 qualifying studies are provided in Appendix B. The qualifying studies provided data regarding two intervention arms that evaluated expanding access only and 15 intervention arms that included expanded access combined with other interventions. Types of expanded access included drop-in clinics (32,57,63,67,72), increased hours on nights and weekends (31,84,107), providing vaccinations in emergency departments (156,164), dedicated vaccination clinics (73,111), special vaccination appointments (36,37), vaccination stations for inpatients (162), and transportation assistance (33). Most multicomponent interventions included client reminder/recall (31,32,33,36,37,57,63,67,72,84). Other components used with expanded access included provider education (31,32,33,36,63), clinic-based education (31,33,36,107), reducing costs (32,67,156), standing orders (63,72,162), communitywide education (32,111), client incentives (33), WIC interventions (32), home visiting (33), and assessment and feedback (36).

Three qualifying studies (84,111,162) presented data that could not be expressed as a percentage point change in coverage. The remaining studies presented data regarding 12 multicomponent intervention arms and 2 single-component intervention arms. The overall median change was 10% (range, -8%-35%). Two studies that evaluated expanded access only found changes of 3% and 7% only one of these reached a level of statistical significance. Studies that evaluated expanding access in combination with other interventions found a median change of 13% (range, -8%-35%). Neither of the two studies of emergency department vaccination programs (156,164) found results that were significantly different from zero.

Any of several reasons could explain the fact that multicomponent interventions that include expanding access were effective in improving vaccination coverages, whereas expanding access only is less effective. Possibly, this finding reflects -

- the existence of more studies of multicomponent interventions;
- greater intensity and, thus, greater effectiveness of multicomponent interventions; or
- synergy between components of multicomponent interventions (i.e., the whole is more effective than the sum of the parts).

Another possibility is that only expanding access might not cause large increases in acceptance of vaccinations but could increase the feasibility of using other components (e.g., standing orders or reminders).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccines. Populations have included adults (36,37,57,63,67,72,73,162) and children (31,32,33,84,111,156,164). Adolescents have been studied in mother-infant pairs but not regarding their own vaccinations (107). Studies have been conducted in a variety of settings including managed care (33,63), community clinics (57,67), Veterans' Administration (VA) hospitals and clinics (72,162), academic settings (37,107), private practices (36), public health clinics (31,84), and as a part of communitywide interventions (32,111).

##### Evidence of Other Positive or Negative Effects

No other positive or negative effects were sought in this review.

##### Economic Evidence

Our search identified one economic evaluation of a multicomponent intervention that included expanding access (120). Details of that study are provided in Appendix C. That study estimated the costs of an intervention that included expanding access to vaccination services, multiple education and health promotion activities, and possibly, provider assessment and feedback. The adjusted estimate of average program costs based on that study is $7.65/vaccination delivered.

#### Barriers to Intervention Implementation

Potential barriers to implementation of programs to expand access to vaccination services in medical settings include (a) difficulties coordinating between settings; (b) lack of appropriate records; (c) clients' difficulty accurately recalling immunization status; (d) high numbers of clients with contraindications to vaccinations (e.g., high numbers of febrile children in emergency department settings); and (e) lack of a relationship between vaccination programs and primary missions of settings.

#### Recommendations

##### Multicomponent Interventions

According to the Guide's rules of evidence, multicomponent interventions that include expanding access to vaccinations in clinical settings are strongly recommended on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

##### Single-Component Interventions

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of expanding access to vaccinations in medical settings when these interventions are used alone. Until more and better information becomes available, communities might choose to make decisions regarding single-component interventions on grounds other than available studies.

## Vaccination Interventions in Nonmedical Settings

Vaccination interventions in nonmedical settings involve efforts to encourage vaccination of important target populations in places where they congregate (e.g., child care centers, schools, and WIC locations). At a minimum, these interventions involve assessment of each child's immunization status and either referral of underimmunized persons to healthcare providers or provision of vaccinations on-site. Other services can include education, provision of vaccinations, and incentives to accept vaccinations.

### 10 Vaccination Programs in WIC Settings

Vaccination programs in WIC settings involve efforts to encourage vaccination of a low-income target population in this nonmedical setting. At a minimum, vaccination-promoting strategies in WIC require assessment of each child's immunization status and referral of underimmunized children to a healthcare provider. Other services can include education, provision of vaccinations, or incentives to accept vaccinations (e.g., monthly voucher pickup, which requires more frequent WIC visits when children are not up-to-date).

- WIC interventions improve vaccination coverage in children whether used alone or as part of a multicomponent intervention.
- All available studies evaluated assessing the immunization status of WIC clients and either providing vaccinations on-site or referring clients elsewhere for vaccination. Some interventions also used monthly voucher pickup or provided free vaccinations.

#### Background

WIC (the Special Supplemental Nutrition Program for Women, Infants, and Children) is a federal grant program administered by the U.S. Department of Agriculture and implemented through state health departments and American Indian and Alaska Native tribal organizations. WIC provides supplemental foods, healthcare referrals, and nutrition education for low-income women, infants, and children who are found to be at nutritional risk. The program is required to serve as a gateway to, and coordinator for, other health services, including vaccinations. WIC is the single largest point of access to health-related services for low-income preschool children. The program serves over 45% of the U.S. birth cohort and, in some cities, serves up to 80% of low-income infants. In general, participants visit WIC sites every 2-3 months to receive nutrition services and to pick up food vouchers; more comprehensive health status evaluations are conducted every 6-12 months. Voucher restrictions are used to closely monitor high-risk clients in the WIC program. They require families to return to the WIC site more frequently than would otherwise would have been required, usually monthly. Here, such requirements are referred to as monthly voucher pick up.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 10 studies regarding the effectiveness of WIC interventions (32,148,165,166,167,168,169,170,171,172). One additional paper provided more information regarding an already included study (173). Six studies were not included in the review because of limited execution (167,168,169,170,171,172). Details regarding the four qualifying studies are provided in Appendix B. Three studies were conducted entirely among WIC clients. One study compared education, assessment, referral, and either escort to a vaccination clinic or monthly voucher pickup with education, assessment, and referral only. Both intervention arms resulted in relatively small (approximately 4% changes in both groups) but significant improvements in vaccination coverage from baseline coverages of 94%. Two studies compared WIC interventions with no intervention. One of these compared various combinations of education, assessment, referral, free vaccinations, and monthly voucher pickup with usual care and found an 9% change in the intervention groups relative to the control group and few substantial differences between intervention groups (166). The other study compared assessment, education, monthly voucher pickup, and free vaccinations plus various combinations of referrals for vaccination or on-site vaccination provision. That study found a 34% change in vaccination coverage and did not find substantial differences in effectiveness based on specific strategies used for vaccination provision or referral (148). A final study used WIC interventions as part of a comprehensive multicomponent intervention and found a 12% improvement in coverage attributable to all components combined (32).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccines. All qualifying studies were conducted in urban areas among disadvantaged, predominantly minority, children. These studies did not include nonurban areas or nonminority populations.

##### Evidence of Other Positive or Negative Effects

Many WIC providers are concerned that vaccination requirements or monthly voucher pickup will serve as a disincentive for WIC participation. Two qualifying studies evaluated the effect of WIC programs regarding dropout rates. One of these (165) enrolled 377 children who received assessment and escort, 281 children who received assessment and referral, and 178 children who received assessment and monthly voucher pickup. Nine children (eight at voucher sites) dropped out during the study period. Another study (148) found that dropout rates remained stable over time in the intervention group (average 40%) but increased over time in the comparison group (average 34%). These data (small absolute dropout rates in one study and small absolute differences in dropout rates in another study) do not demonstrate that vaccination interventions in WIC cause substantial increases in WIC dropout.

##### Economic Evidence

Our search identified two economic evaluations of WIC interventions (148,173). One of these reported cost-effectiveness ratios of three different variations of a WIC intervention differing primarily in methods of referral or vaccination provision (148). Details of that study are provided in Appendix C. Adjusted cost-effectiveness ratios based on that study ranged from $34 to $84/fully vaccinated child. Adjusted average cost of assessments based on a second study (173) were $2.65/assessment, for interventions using an on-site vaccination nurse, and $1.28/assessment, for interventions using other strategies to promote vaccination.

#### Barriers to Intervention Implementation

Barriers to implementation of a vaccination program in WIC settings might include difficulties coordinating two programs and philosophical objections to monthly voucher pickup policies among some WIC providers and managers.

#### Recommendation

According to the Guide's rules of evidence, interventions in WIC settings are recommended on the basis of sufficient scientific evidence of effectiveness in improving vaccination coverage.

### 11 Home Visits

Home visits to promote vaccinations involves providing face-to-face services to clients in their homes. Services can include education, assessment of need, referral, and provision of vaccinations. Home-visiting interventions also can involve telephone or mail reminders.

- Home-visiting interventions improve vaccination coverage.
- Most available studies were conducted in socioeconomically disadvantaged populations.
- At least when applied only to improve vaccination coverage, home-visiting interventions can be highly resource-intensive relative to other available options for improving vaccination coverage.

#### Background

In the United States, home-visiting interventions are usually targeted toward subpopulations that are difficult to reach (e.g., those persons living in public housing communities or persons living in rural areas).

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 15 studies regarding the effectiveness of home visits to improve vaccination coverage (33,73,174,175,176,177,178,179,180,181,182,183,184,185,186). One additional paper provided more information regarding an already included study (89). Of these, eight had limited execution and were therefore not included in the review (174,177,178,179,180,181,184,185). One study evaluated home visits both as a component of a complex multicomponent intervention and as used alone (33). The evaluation of home visits only in that study had limited execution; therefore, only the multicomponent intervention from that study is included in this review. Details of the seven qualifying studies are presented in Appendix B. Five studies evaluated home visiting with or without client reminders and case management (73,175,176, 182,186). Two studies (33,183) evaluated complex multicomponent strategies including home visits. These 7 studies found changes in vaccination coverages ranging from -1% to 49% (median, 10%). Two studies of home-visiting-only interventions found changes in coverage of -1% and 10%. Multicomponent interventions demonstrated changes in coverage ranging from 2% to 20% (median. 13%).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to other settings, populations, and vaccines. Studies included adults (73,175) and children (33,176,182,183,186). Many studies included urban populations (33,182,183,186) and clients of low socioeconomic status (33,182,183,186). One study included rural populations (182). Home visits has not been studied among adolescents or in interventions to increase delivery of hepatitis B or pneumococcal vaccinations.

##### Evidence of Other Positive or Negative Effects

No other positive or negative effects of this intervention were sought in this review.

##### Economic Evidence

Our searches identified four economic evaluations of home visits (179,182,186,187). Two reported cost-effectiveness ratios (182,186), and two reported average costs (179,187). Details of these studies are provided in Appendix C. Adjusted average costs based on the data in those studies were $22/child vaccinated and $130/vaccination. Adjusted cost-effectiveness ratios based on those studies ranged from $513 to $13,020 per additional vaccination.

#### Barriers to Intervention Implementation

Potential barriers to implementing home-visiting programs include need for staff training and concerns regarding staff safety.

#### Recommendation

According to the Guide's rules of evidence, home visits to improve vaccination coverage is recommended on the basis of sufficient scientific evidence of effectiveness.

### 12 Vaccination Programs in Schools

School-based vaccination interventions are intended to improve delivery of vaccinations to school attendees aged approximately 5-18 years. School-based interventions usually include vaccination-related education of students, parents, teachers, and other school staff plus either provision of vaccinations or referral for vaccinations. These interventions can also involve other components (e.g., providing incentives, acquiring written consent from parents or guardians, and administering vaccinations). Vaccination requirements for school attendance are reviewed elsewhere in this chapter.

- Only one qualifying study evaluating the effectiveness of school-based vaccination programs was identified.
- No comparative studies evaluating the effectiveness of school-based vaccination programs to improve vaccination coverage were identified.

#### Background

School-based vaccination programs could provide a unique opportunity for reaching adolescents to provide vaccinations and other preventive services because in the United States, approximately 99% of children aged 11 and 12 years attend school (188). School-based vaccination programs could track each student's immunization status, identify those who have missed doses, and ensure vaccine series completion (e.g., with hepatitis B vaccine) among most students. School-based vaccination programs are often collaborations between schools, local health departments, private hospitals, and community clinics.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified four studies regarding the effectiveness of school-based vaccination programs for improving coverage (51,75,109,189). Of these, three had limited execution and were not included in the review (51,75,109). Details of the single qualifying study are provided in Appendix B. The qualifying study (189) evaluated a school-based program to increase delivery of hepatitis B vaccinations to adolescents; the study used multiple components including teacher education, classroom lessons, written client educational materials, and peer and individual incentives to encourage children to bring in their consent forms. Results demonstrated (a) generally positive attitudes toward vaccinations among students and teachers; (b) significant improvements in client knowledge regarding hepatitis B; (c) faster return of consent forms among schools when incentives were used, and (d) vaccination coverage with three doses of hepatitis B vaccine after the intervention of 66% (comparative data not available).

##### Evidence of Other Positive and Negative Effects

No information regarding other positive or negative effects was sought in this review.

#### Barriers to Intervention Implementation

Potential barriers to implementation of vaccination programs in schools might include difficulties coordinating between different programs, need for staff training, disruption of school routines, and concerns regarding confidentiality.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to determine the effectiveness of school-based vaccination interventions because of the small numbers of available studies, limitations in their design and execution, and lack of comparative studies regarding the effectiveness of these interventions to improve vaccination coverage. Until more and better information becomes available, communities might choose to make decisions regarding school-based programs on grounds other than available studies.

### 13 Vaccination Programs in Child Care Centers

Interventions in child care centers involve efforts to encourage vaccination of children aged <5 years. These interventions require assessment of each child's immunization status at (a) entry into child care, (b) at some point during the child's enrollment, or (c) at periodic intervals throughout the child's enrollment. Vaccination interventions in child care centers can also include education or notification of parents, referral of underimmunized children to healthcare providers, and possibly, provision of vaccinations on-site. Vaccination requirements for entry into child care centers are reviewed elsewhere in this chapter.

- Only one study evaluated the effectiveness of vaccination interventions in child care settings, and it was not included in the review because its execution was limited.

#### Background

Children in child care centers are at increased risk for communicable diseases (190). In 1995, approximately 31% of preschool age children were being cared for in child care centers (Report of the Children's Health Working Group, March 1998 Draft). Interventions in child care centers can result in increased attendance in clinical settings through referrals or possibly by directly increasing coverage through delivering vaccinations on-site.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified only one study (191) regarding the effectiveness of interventions in child care centers to improve vaccination coverage. That study was not included in the review because of limited execution. Absence of qualifying studies does not allow us to make an assessment of the effectiveness of child care center programs.

##### Evidence of Other Positive or Negative Effects

No other positive or negative effects were sought in this review.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of interventions in child care centers because only one study was identified and it was limited in its design and execution. Until more and better information becomes available, communities might choose to make decisions regarding interventions in child care centers on grounds other than available studies.

### Research Issues for Enhancing Access to Vaccination Services

#### Effectiveness

The effectiveness of recommended and strongly recommended interventions in this section (i.e., reducing out-of-pocket costs, expanding access in healthcare settings as part of multicomponent interventions, home visits, and vaccination interventions in WIC settings) is established. However, research issues, which contribute to increased or lessened effectiveness, remain regarding the characteristics of these interventions. For example,

- Are programs to reduce out-of-pocket costs similarly effective among persons who are and who are not economically disadvantaged?
- What are the relative effectiveness and economic consequences of strategies that provide home visits for all persons in a defined population versus those that use staged protocols using less-intensive interventions (i.e., reminders) to reach some clients and reserve actual home visits for clients who are hardest to reach?
- What are least- and most-effective combinations of services in multicomponent interventions, including multicomponent interventions that incorporate increasing access to vaccination services in healthcare settings?
- What are the least- and most-effective combinations of services in WIC interventions?
- How accurate are vaccination data in WIC settings, and how does data accuracy impact effectiveness?

Because the effectiveness of vaccination programs in child care centers, vaccination programs in schools, and single-component interventions to increase access to vaccination in healthcare settings has not been established, basic research questions remain.

- Are these interventions effective in improving vaccination coverage?
  - - Of the range of strategies that have been used to expand access to vaccination services in healthcare settings, which are the most- and least-useful?
- What attributes of these programs contribute to effectiveness or lack thereof?

#### Applicability

Each recommended and strongly recommended intervention should be applicable in most relevant target populations and settings. However, possible differences in the effectiveness of each intervention for specific subgroups of the population could not be determined. Several questions regarding the applicability of these interventions in settings and populations other than those studied remain.

- What strategies would be most effective for improving access to vaccinations among adolescents?
- Is effectiveness of WIC interventions in rural areas similar to that described in urban areas?

#### Other Positive and Negative Effects

In general, studies included in this review did not report on other positive and negative effects of these interventions. Therefore, research regarding the following questions would be useful:

- Do programs to reduce out-of-pocket costs adversely affect development or adoption of new vaccines?
- Do any of these interventions have positive or negative effects regarding subsequent use of primary care?
- Do home visits result in identification of child abuse or neglect?
- Do home visits result in reporting of possible abuse or neglect that is not subsequently confirmed?
- Do WIC interventions result in dropout?
- Do interventions to increase access to vaccinations in healthcare settings interfere with other functions of these settings, and if so, how can this effect be minimized?
- Do these interventions result in other positive changes in use of prevention services or healthcare as well as improving vaccination coverage?

#### Economic Evaluations

In general, available economic information was sparse. Therefore, considerable research is warranted regarding the following questions:

- What are the costs of these interventions?
- How do costs per additional child vaccinated compare with other interventions to improve vaccination coverage?
  - - Are home-visiting programs cost-effective relative to other interventions to improve vaccination coverage?
  - - Can strategies that are designed to improve vaccination coverage and other outcomes concurrently improve cost-effectiveness of these strategies?
  - - Are home-visiting programs that address more than one issue more or less cost-effective than programs addressing vaccinations only?
- How do specific characteristics of these interventions contribute to economic efficiency?
  - - What are the relative economic consequences of universal programs to reduce out-of-pocket costs versus programs intended for persons whose need is greatest?
  - - What combinations of components in multicomponent interventions are most cost-effective?
  - - Are staged home-visit protocols more cost-effective than those that are not?
  - - What are the most cost-effective combinations of services for WIC programs?
- What is the cost-benefit or cost-utility of these interventions?

#### Barriers

- How can these interventions be implemented with minimal administrative burden placed on providers or systems and minimal disruption of the settings' primary missions.
- How can reducing out-of-pocket costs be effectively implemented given the fragmentation of payment mechanisms in the United States?
- Can registries help to overcome lack of current immunization status that is sometimes a barrier to implementing these interventions.

## Provider-Based Interventions

In the United States, most people accept the need for vaccinations, and they are seen periodically in healthcare settings. Unfortunately, providers often miss opportunities to vaccinate. Provider-based interventions are implemented primarily through healthcare systems in settings with the goal of reducing missed opportunities. The provider-based interventions reviewed in this chapter include provider recall/reminder, provider assessment and feedback, standing orders, and provider education-only interventions.

### 14 Provider Reminder/Recall

Provider reminder/recall interventions inform those who administer vaccinations that individual clients are due (reminder) or overdue (recall) for specific vaccinations. Techniques by which reminders are delivered - in client charts, by computer, by mail, or other - and content of reminders can vary. Interventions that incorporate elements of both reminders and standing orders are reviewed with standing orders in this chapter.

- in adults, adolescents, and children;
- whether used alone or as part of a multicomponent intervention;
- across a range of intervention characteristics (e.g., computerized or simple reminders, checklists, or flowcharts); and
- in a range of settings and populations.

#### Background

Provider reminder/recall systems make information regarding the client's immunization status available to providers either manually or through a computerized system. This information is then conveyed to the provider before, during, or after a scheduled appointment.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 60 studies regarding the effectiveness of provider reminder/recall (36,37,38,42,43,52,53,64,69,74,78,102,104,106,110,112,113,114,115,139,141,152,155,164,177,182,192-225). Eight additional papers provided more information regarding an already included study (86,90,92,93,226,227,228,229). Thirty-one studies were not included in the review because of limited execution (69,102,104,110,112,113,115,139,141,152,155,177,193,194,213,214,215,216,217,218,220) or least-suitable designs (53,78,108,192,197,198,202,210,211,224). Details of the 29 qualifying studies are provided in Appendix B. The qualifying studies reported on 21 intervention arms evaluating provider reminder/recall only and 15 evaluating multicomponent interventions including provider reminder/recall. Interventions typically involved chart reminders, checklists, or flowcharts, or computerized reminders made available to providers at the time of client visits. One study evaluated letter reminders sent from an emergency department between clinic visits (164). Multicomponent interventions also included client reminder/recall (36,38,42,43,52,74), clinic-based education (36,37,42,114,205), provider assessment and feedback (36,42,182,204,205,209,223), provider education (36,182,209). communitywide education (38), and expanded access (36).

Five qualifying studies presented data regarding one or more intervention arms that could not be expressed as a percentage point change in coverage (38,114,164,204,222). Remaining studies provided data regarding 17 single-component intervention arms and 12 multicomponent intervention arms. Overall, the studies found a median change in coverage of 17% (range, 1%-67%). Studies that evaluated provider reminder/recall only found a median change in coverage of 17% (range, 1%-67%). Studies that evaluated provider reminder/recall as part of a multicomponent intervention found a median change of 14% (range, 1%-36%).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccines. Affected populations included adults (36,37,42,43,52,60,64,74,114,195,196,199,200,201,203,206,207,208,209,212,212,219,225), adolescents (204), and children (38,164,182,205,221). Studies have included a range of providers including residents (37,43,64,74,114,195,196,204,205,206,209,212,219,221,222,223), physicians who have completed their training, (36,37,64,74,161,173,174,179,190,191) and nonphysician vaccination providers (36,37,64,74,206,207,207,212,221,221,222). Physician specialties included internal medicine (36,43,114,196,201,206,209,212,219,222), family medicine (36,37,52,64,74,195,203,204,205,207,225), and pediatrics (221). Most studies have been done in outpatient settings, but inpatient settings are also represented (200,208). Most studies have been done in academic clinical settings, but other settings are also represented including community health centers (221,225), managed care (42), private practice (36,52), community hospitals (200), and communitywide settings (38). Studies have assessed the effectiveness of these interventions to improve vaccination delivery of MMR (38,164,182,204,205,221), DTP (164,182,205,221), OPV (164,182,205,221), Hib (164,182,221), influenza (36,37,42,43,64,195,196,199,200,201,206,207,209,212,222), pneumococcal (43,196,199,201,206,207,208,209,212,212,219), and Td (43,52,64,74,114,196,203,222,225). We did not find studies of the effectiveness of this intervention to improve delivery of hepatitis B vaccinations.

##### Evidence of Other Positive or Negative Effects

Several qualifying studies that assessed nonvaccination outcomes (e.g., improved delivery of other prevention services or clinical care) found improvements in some outcomes other than vaccination (74,196,212,222,223). Other positive or negative effects were not sought in this review.

##### Economic Evidence

Our search identified three studies (52,93,192) (Appendix C). Data from a study estimating the cost-effectiveness of provider reminders-only documents an adjusted cost-effectiveness ratio of $0.70/additional vaccination. This cost-effectiveness ratio is probably an underestimate because it does not include the cost of producing reminders. A second study estimated the cost-effectiveness of an intervention that included both client and provider reminders (52). The adjusted cost-effectiveness ratio based on that study was $4/additional vaccination. A final study estimated the cost-effectiveness of a program that assessed the immunization status of hospitalized children by contacting the children's usual physicians, and hospital physicians were reminded to vaccinate the children before they left the hospital (192). The adjusted cost-effectiveness ratio based on that study was $300/ fully vaccinated child.

#### Barriers to Intervention Implementation

Five studies (139,182,207,218,221) found that some settings had difficulty placing reminders in charts or using reminders when provided. This suggests that administrative burden can be a barrier to reminder use. Lack of information infrastructure could also be a barrier to reminder use.

#### Recommendation

According to the Guide's rules of evidence, provider reminder/recall interventions are strongly recommended on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

### 15 Assessment and Feedback for Vaccination Providers

Provider assessment and feedback involves retrospectively evaluating the performance of providers in delivering one or more vaccinations to a client population and giving this information to providers. Assessment and feedback interventions can also involve other activities (e.g., incentives or benchmarking [i.e., comparing performance to a goal or standard]).

- in adults and children;
- whether used alone or as part of a multicomponent intervention; and
- across a range of settings and populations.

#### Background

Provider assessment and feedback can result in improvements in vaccination coverage either by changing provider knowledge, attitudes, and behavior, or by stimulating use of additional changes in the vaccination delivery system (e.g., reminders or standing orders). Evaluation of provider assessment and feedback is timely because (a) information systems are improving and are increasingly common; (b) most vaccinations are delivered in the private sector; and (c) such quality-assurance approaches as the Healthplan Employer Data and Information Set (HEDIS) are being used more often.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 27 studies regarding the effectiveness of assessment and feedback (36,42,47,58,69,81,139,182,194,197,204,205,209,211,213,218,220,223,230,231,232,233,234,235,236,237,238). Four additional papers provided more information regarding an already included study (86,94,146,239). Thirteen studies were not included in the review because of limited execution (69,81,139,194,211,213,218,220,231,232,233,237,238). Details regarding the 14 qualifying studies are provided in Appendix B. Qualifying studies presented data regarding seven intervention arms evaluating assessment and feedback only and nine intervention arms evaluating assessment and feedback used as a part of a multicomponent intervention. Generally, assessment and feedback components of interventions were not described in detail (e.g., content, frequency, method of delivery, or associated characteristics such as benchmarking or incentives). Some studies reported on use of assessment and feedback only; several evaluated assessment and feedback used with financial (230,234) or nonfinancial (235) incentives. One study found that assessment and feedback to individual physicians might have been more effective than assessment and feedback to the chief of service, but alternative explanations for this finding exist. All but one of the multicomponent interventions (47) incorporated provider reminder/recall as well as assessment and feedback. Multicomponent interventions also included provider education (36,182,197), client reminders (36,182,197), and clinic-based education (36,42,205).

Three qualifying studies (204,230,236) presented data that could not be expressed as a percentage point change in vaccination coverage. Remaining studies provided data regarding eight multicomponent intervention arms and five single-component intervention arms. Overall, these studies demonstrated increases in vaccination coverage ranging from 1% to 43% (median, 16%). Studies that evaluated provider assessment and feedback only found a median coverage increase of 16% (range, 9%-41%). Studies that evaluated provider assessment and feedback as part of a multicomponent strategy found a median change of 17% (range, 1%-43%). Several studies have demonstrated that improvements in coverage can be maintained or further improved over several years of follow-up (197,234,235).

##### Evidence of Applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, populations, and vaccines. Studies have included adults (36,42,47,58,197,209,223,230,234,), adolescents (204), and children (182,205,235,236), providers including resident physicians (197,204,205,209,234), physicians who have completed their training (36,42,47,58,205,236), and nonphysician vaccination providers (205. Physician specialties included internal medicine (36,47,58,197,209,234). family medicine (36,204,205), and general practice (236). Studies have been conducted in a range of settings including private practice (36,47,58), managed care (42), public health (235), and community health centers (230), and academic settings (197,204,205,209,223,234). Studies have assessed the effectiveness of these interventions to improve coverage with MMR (182,204,205,235,236), DTP (182,205,235,236), OPV (182,205,235,236), Hib (182), influenza (36,42,47,58,197,209,230,234) pneumococcal (197,223,234), and Td (197,234). The body of evidence did not include studies of interventions to improve delivery of hepatitis B vaccinations.

##### Evidence of Other Positive or Negative Effects

Several qualifying studies that assessed nonvaccination outcomes (e.g., improved delivery of other prevention services or clinical care) found improvements in some outcomes other than vaccination (197,233,230). Other positive or negative effects were not sought in this review.

##### Economic Evidence

No economic evaluations of assessment and feedback interventions were identified.

#### Barriers to Intervention Implementation

Potential barriers to use of assessment and feedback include lack of an adequate information infrastructure and administrative burden on providers and systems.

#### Recommendation

According to the Guide's rules of evidence, assessment and feedback of vaccination coverage information to providers is strongly recommended on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

### 16 Standing Orders

Standing orders involve interventions in which nonphysician personnel prescribe or deliver vaccinations to client populations by protocol without direct physician involvement at the time of the interaction. Settings in which this occurs include clinics, hospitals, and nursing homes. Dedicated vaccination clinics often operate under standing orders, but we did not consider standing orders in that context as an intervention for the purposes of this chapter.

- improve vaccination coverage whether used alone or as part of a multicomponent intervention; and
- are effective in such settings as hospitals, clinics, and nursing homes.

#### Background

Requirements for physical examinations and lack of personnel to administer vaccines are two administrative barriers that might contribute to missed opportunities to vaccinate. Empowering nonphysician personnel to deliver vaccinations without physician involvement at the time of the visit could reduce barriers to vaccination and missed opportunities, resulting in improved vaccination delivery.

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified 16 studies regarding the effectiveness of standing orders (36,63,72,110,118,155,162,200,217,240,241,242,243,244,245,246). Two additional papers provided more information regarding an already included study (91,247). Five studies were not included in the review because of limited execution (110,155,217,241,246). Details of the 11 qualifying studies are provided in Appendix B. Qualifying studies provided data regarding six intervention arms that evaluated standing orders only and five intervention arms that evaluated multicomponent interventions that included standing orders. Multicomponent interventions included expanding access (36,63,72,162), client reminder/recall (36,63,72), clinic-based education (36,118), provider education (36,63), provider reminder/recall (36), and assessment and feedback.

Two studies presented data that could not be expressed as a percentage point change in vaccination coverage (162,244). Overall, eight studies of standing orders to improve vaccination coverage in adults found a median change of 28% (range, 6%-81%). Studies in which standing orders were used alone found a median change of 51% (range, 30%- 81%). Studies in which standing orders were used as part of a multicomponent strategy found a median change of 16% (range, 6%-26%). Most studies lasted less than a year, but one found continuing improvements over 5 years (91).

A single study in children (240) found modest declines in missed opportunities to vaccinate at non-well-child visits but no overall improvement in vaccination delivery. Given (a) the greater complexity of vaccination protocols in children as compared with that for adults; (b) the identification of only a single qualifying study of standing orders to increase vaccination coverage in children; (c) limitations in that study's design and conduct; and (d) reported effects regarding vaccination coverage that were not substantially different from zero, we concluded that insufficient evidence exists to assess the effectiveness of standing orders to improve vaccination coverage in children.

##### Evidence of Applicability

The body of evidence used to assess effectiveness of standing orders in adults was used to assess the applicability of these interventions to different settings, populations, and vaccines. Studies have been conducted in community (200) and other hospitals (72,162,243), nursing homes (245), and a variety of outpatient settings including private practices (36), managed care organizations (63), Veteran's Administration clinics (72), and academic clinical organizations (118,242,244). Studies have evaluated the effectiveness of standing orders to improve delivery of both influenza (36,63,72,118,162,200,242,244) and pneumococcal vaccinations (118,243,245). No studies were found evaluating standing orders to improve vaccination in adolescents or to improve delivery of hepatitis B or Td vaccinations.

##### Evidence of Other Positive or Negative Effects

Other positive or negative effects were not sought in this review.

##### Economic Evidence

No economic evaluations of standing orders were identified.

#### Barriers to Intervention Implementation

Potential barriers to implementing standing orders could include (a) difficulties encouraging effective interprofessional communication and shared responsibilities and (b) the burden of standing orders on providers and systems. One study found that a nurse-guided algorithm to vaccinate children in a busy pediatric clinic could be completed in only 43% of eligible children ( 240 ). Alternatively, in some settings, standing orders could reduce the burden on physicians and increase clinic efficiency.

#### Recommendations

##### Vaccinating Adults

According to the Guide's rules of evidence, standing orders are strongly recommended for vaccinating adults on the basis of strong scientific evidence of effectiveness in improving vaccination coverage.

##### Vaccinating Children

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of standing orders for vaccinating children.

### 17 Provider Education Only

Provider education involves giving information regarding vaccinations to providers to increase their knowledge or change their attitudes. Techniques by which information is delivered can include written materials, videos, lectures, continuing medical education programs, and computerized software. Interventions that have additional features (e.g., provider reminders or assessment and feedback) or that are used in combination with other interventions (e.g., multicomponent interventions that include education) are reviewed elsewhere in this chapter.

- Two studies of low-intensity interventions evaluated the impact of these interventions regarding vaccination coverage. One documented small and nonsignificant impacts regarding coverage; the other study found that provider education produced smaller impacts regarding coverage than provider reminder/recall interventions or standing orders.
- Three studies of provider education-only interventions found variable impacts regarding provider knowledge and attitudes. The best-described and most-intensive intervention produced improvements in provider knowledge and attitudes.

#### Background

Provider education is based on the assumption that provider knowledge regarding vaccination will affect physician behavior in a positive manner. Provider education could stimulate them to deliver additional vaccinations, change provider-client interactions to increase client acceptance of vaccinations, or motivate providers to implement other interventions (e.g., reminder/recall systems or standing orders).

#### Review of Evidence

##### Evidence of Effectiveness

Our search identified six studies regarding provider education-only interventions (200,216,248,249,250,251). An additional paper provided more information regarding an already included study (229). Two studies had limited execution and were therefore not included in the review (216,248). Details regarding the four qualifying studies are provided in Appendix B. Two studies regarding adults evaluated vaccination coverage as an outcome. One evaluated a fact sheet attached to each client's chart and found small and nonsignificant percentage point changes and no change in provider knowledge and attitudes (249). The other study used provider education as the comparison group in a study that evaluated provider reminders and standing orders (200) and found changes in coverage of 30% and 7%, compared with standing orders and provider reminders, respectively.

Two studies evaluated the effectiveness of provider education regarding knowledge and attitudes (250,251). These studies found improvements in provider knowledge and attitudes after dissemination of national guidelines for hepatitis B and implementation of an innovative problem-based learning protocol in medical schools. With one exception (251), available studies of provider education evaluated interventions that were not very intensive. Available data cannot be generalized to more intensive efforts. Also, provider education is a part of several effective multicomponent interventions, including provider reminders, assessment and feedback, and educational interventions.

##### Evidence of Other Positive and Negative Effects

No information regarding other positive or negative effects was sought in this review.

#### Recommendation

According to the Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of provider education-only interventions on the basis of (a) the small numbers of available studies; (b) limitations in their design and conduct; and (c) small effect sizes. Until more and better information becomes available, communities might choose to use provider education in conjunction with other interventions.

### Research Issues for Provider-Based Interventions

#### Effectiveness

The effectiveness of recommended and strongly recommended interventions in this section (i.e., provider reminder/recall, provider assessment and feedback, and standing orders) is established. However, research issues regarding the effectiveness of these interventions remain.

- Which characteristics of provider-based interventions contribute to increased or lessened effectiveness?
  - - How do content and method of delivery of provider reminder/recall relate to effectiveness?
  - - What components of assessment and feedback interventions (e.g., incentives or benchmarking) contribute most to effectiveness?
  - - How do different practice settings (e.g., independent private practice settings versus hospital management organization settings) contribute to increased or lessened effectiveness of various interventions?
  - - What is the effectiveness of HEDIS, as a form of assessment, feedback, and benchmarking, in improving vaccination coverage? In independent private-practice settings? In hospital management organization settings?
  - - What intermediate outcomes contribute to the effectiveness of provider assessment and feedback (e.g., provider's knowledge, attitudes, or behavior; additional interventions; or other factors)?
  - - What are the least- and most-effective combinations of services in multicomponent interventions?

- Can registries provide a backbone for effective interventions (e.g., provider reminder/recall)?
- How easily can systems for provider reminders or assessment and feedback that encourage the use of one clinical preventive service be adapted for other services?
- What is the relative effectiveness of provider reminders or assessment and feedback that focus on immunizations versus reminders or assessment and feedback that rotate from one clinical preventive service to another?

Because the effectiveness of provider education-only interventions has not been established, basic research questions remain.

- Are these interventions effective in improving vaccination coverage?
- Are these interventions effective in increasing provider knowledge or promoting positive provider attitudes toward vaccination?
- What attributes of provider education-only programs - medium, message, or intensity - contribute to effectiveness or lack thereof?
- Are intensive provider education programs more effective than other programs that are less intensive?

#### Applicability

Each recommended and strongly recommended provider-based intervention should be applicable in most relevant target populations and settings. However, possible differences in the effectiveness of each intervention for specific subgroups of the population could not be determined. Several questions regarding the applicability of these interventions in settings and populations other than those studied remain.

- Are these interventions as effective in improving vaccination coverage in adolescents as they are in children and older adults?
- Do significant differences exist regarding the effectiveness of these interventions based on the level of scale at which they are delivered (i.e., communitywide provider reminders from a registry versus managed care-based systems versus office-practice-based systems)?

#### Other Positive and Negative Effects

With the exception of some discussion of improved use of other clinical and preventive care, studies included in the review did not report on other positive and negative effects of these interventions. Therefore, research regarding the following questions would be useful:

- Do provider-based interventions to increase vaccination interfere with office flow or efficiency, and if so, how can this effect be minimized?
- Do provider-based interventions result in other positive changes in use of preventive or health care as well as improving vaccination coverage?

#### Economic Evaluations

Generally, available economic information was sparse; therefore, considerable research is warranted regarding the following questions:

- What are the costs of these interventions?
- How do costs per additional child vaccinated compare with other interventions intended to improve vaccination coverage?
- Can strategies that are designed to improve vaccination coverage be used concurrently with other outcomes to improve cost-effectiveness of these strategies?
  - - How do specific characteristics of these interventions contribute to economic efficiency?
  - - What particular characteristics of provider reminder/recall systems contribute most to cost-effectiveness?
  - - What combinations of components in multicomponent interventions are most cost-effective?
  - - How do the opportunity costs of multicomponent versus single-component interventions compare?
  - - What is the cost-benefit or cost-utility of these interventions?

#### Barriers

- How can these interventions be implemented with minimal administrative burden placed on providers or systems?
- Do communitywide registries reduce barriers to use or increase use of provider reminders, provider assessment and feedback, or provider education?
- For provider reminder/recall and provider assessment and feedback, how can the burden on providers (e.g., data entry) be reduced?
  - - Can improved sampling strategies be developed and can meaningful information be extracted from small samples of records?
- How can the uptake of these interventions in private practices be encouraged?

## Appendices

### References

1 Fedson DS. Adult immunization: summary of the national vaccine advisory committee. JAMA. 1994;272:1133-7. [pmid: 7933327].
2 Atkinson WL, Orenstein WA, Krugman S. Resurgence of measles in the United States, 1989-1990. Annu Rev Med. 1992;43:451-63. [pmid: 1580601].
3 Atkinson WL, Markowitz LE, Adams NC, Seastrom GR. Transmission of measles in medical settings-United States, 1985-1989. Am J Med. 1991;91:320S-4S. [pmid: 1928187].
4 Centers for Disease Control and Prevention. Prevention of varicella: recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR. 1996;45(RR-11):1-36.
5 Centers for Disease Control and Prevention. Prevention and control of influenza: recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR. 1998;47 (RR-6):1-26.
6 American Academy of Family Physicians. Summary of policy recommendations for periodic health examination. Kansas City, MO: American Academy of Family Physicians 1996.
7 American Academy of Pediatrics. 1997 Red Book: report of the Committee on Infectious Diseases. Elk Grove Village, IL: American Academy of Pediatrics 1997.
8 American College of Obstetricians and Gynecologists. Obstetrician-gynecologist and primary-preventive care. Washington DC: American College of Obstetricians and Gynecologists 1993. Need to verify all.
9 American College of Physicians, Task Force on Adult Immunization, Infectious Disease Society of America. Guide for adult Immunization. Philadelphia: American College of Physicians 1994.
10 Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical preventive health care. Ottawa, Canada: Communication Group 1994:386.
11 Centers for Disease Control and Prevention. Recommended childhood immunization schedule-United States, 1998. MMWR. 1998;47(1):8-12. [pmid: 9450723].
12 Centers for Disease Control and Prevention. Immunization of adolescents: recommendations of the Advisory Committee on Immunization Practices, the American Academy of Pediatrics, the American Academy of Family Physicians, and the American Medical Association. MMWR. 1996;45(RR-13):1-16.
13 Centers for Disease Control and Prevention. Update on adult immunization: recommendations of the Immunization Practices Advisory Committee (ACIP). MMWR. 1991;40(No. RR-12):1-52.
14 U.S. Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Baltimore, MD: Williams and Wilkins, 1996.
15 Peter G. Childhood immunizations [review]. N Eng J Med. 1992;327:1794-800.
16 Centers for Disease Control and Prevention. National, state, and urban area vaccination coverage levels among children aged 19-35 months-United States, July 1996-June 1997. MMWR. 1998;47(6):108-16. [pmid: 9480412].
17 Centers for Disease Control and Prevention. Vaccination coverage by race/ethnicity and poverty level among children aged 19-35 months-United States, 1996. MMWR. 1997;46:963-8. [pmid: 9347908].
18 Centers for Disease Control and Prevention. Influenza and pneumococcal vaccination levels among adults aged < 65 years-United States, 1997. MMWR. 1998;47:797-802. [pmid: 9776166].
19 Gershon AA, Gardner P, Peter G, Nichols K, Orenstein W. Quality standards for immunization. Guidelines from the Infectious Diseases Society of America. Clin Infect Dis. 1997;25:782-6.
20 Tannenbaum TN, Gyorkos TW, Abrahamowicz M, et al. Immunization delivery methods: practice recommendations. Can J Public Health. 1994;85(suppl 1):S37-S40. [pmid: 7987757].
21 Gyorkos TW, Tannenbaum TN, Abrahamowicz M, et al. Evaluation of the effectiveness of immunization delivery methods [review]. Can J Public Health. 1994;85(supp l):S14-S30. [pmid: 7987755].
22 Centers for Disease Control and Prevention. Programmatic strategies to increase vaccination coverage by age 2 years-linkage of vaccination and WIC services: recommendations of the Advisory Committee on Immunization Practices. MMWR. 1996;45:217-8. [pmid: 8609878].
23 Centers for Disease Control and Prevention. Programmatic strategies to increase vaccination rates-assessment and feedback of provider-based vaccination coverage information: recommendations of the Advisory Committee on Immunization Practices. MMWR. 1996;45:219-20. [pmid: 8609879].
24 Centers for Disease Control and Prevention. Standards for pediatric immunization practices. Atlanta, GA: U.S. Department of Health and Human Services, CDC, National Immunization Program, 1996.
25 Public Health Service. Healthy people 2000: national health promotion and disease prevention objectives. Washington, DC: U.S. Department of Health and Human Services, Public Health Service,1991; DHHS publication no. 91-50212, 1991.
26 Carter H. Measles and rubella immunisation in Fife. Midwife, Health Visitor, and Community Nurse. 1988;24:72-4.
27 Chiu TT, Barata SL, Unsicker DM, Brennan L. Community mobilization for preschool immunizations: the "Shots by Two" project. Am J Public Health. 1997;87:462-3. [pmid: 9096555].
28 O'Sullivan AL, Jacobsen BS. Randomized trial of a health care program for first-time adolescent mothers and their infants. Nurs Res. 1992;41(4):210-5. [pmid: 1408861].
29 Oeffinger KC, Roaten SP, Hitchcock MA, Oeffinger PK. Effect of patient education on pediatric immunization rates. J Fam Pract. 1992;35:288-93. [pmid: 1517726].
30 Ohmit SE, Furumoto-Dawson A, Monto AS, Fasano N. Influenza vaccine use among an elderly population in a community intervention. Am J Prev Med. 1995;11:271-6. [pmid: 7495605].
31 Pierce C, Goldstein M, Suozzi K, Gallaher M, Dietz V, Stevenson J. Impact of the standards for pediatric immunization practices on vaccination coverage levels. JAMA. 1996;276:626-30. [pmid: 8773635].
32 Waterman SH, Hill LL, Robyn B, et al. Model immunization demonstration for preschoolers in an inner-city barrio, San Diego, California, 1992-94. Am J Prev Med. 1996;12(Suppl 1):8-13. [pmid: 8874698].
33 Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
34 Cooling N, Sturge G, Meumann F. Flu vaccination recall database. Med J Aust. 1993;159. [pmid: 8123109].
35 Holtmann AG. Economics of U.S. immunization policy. In: Pauly MV, Robinson CA, Sepe SJ, et al. eds. Supplying vaccine: an economic analysis of critical issues. Washington, DC: IOS press; 1996:153-73.
36 Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
37 Lukasik MH, Pratt G. Telephone: an overlooked technology for prevention in family medicine. Can Fam Physician. 1987;33:1997-2001. [pmid: 21263970].
38 Paunio M, Virtanen M, Peltola H, et al. Increase of vaccination coverage by mass media and individual approach: intensified measles, mumps, and rubella prevention program in Finland. Am J Epidemiol. 1991;133:1152-60. [pmid: 2035518].
39 Alemi F, Alemagno SA, Goldhagen J, et al. Computer reminders improve on-time immunization rates. Med Care. 1996;34:OS45-51. [pmid: 8843936].
40 Alto WA, Fury D, Condo A, Doran M, Aduddell M. Improving the immunization coverage of children less than 7 years old in a family practice residency. J Am Board Fam Pract. 1994;7:472-7. [pmid: 7847110].
41 Barnas GP, McKinney WP. Postcard reminders and influenza vaccination. J Am Geriatr Soc. 1989;37. [pmid: 2910979].
42 Barton MB, Schoenbaum SC. Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health. 1990;80:534-6. [pmid: 2327527].
43 Becker DM, Gomez EB, Kaiser DL, Yoshihasi A, Hodge RH. Improving prevention care at a medical clinic: how can the patient help?. Am J Prev Med. 1989;5:353-9. [pmid: 2597431].
44 Bell JC, Whitehead P, Chey T, Smith W, Capon AG, Jalaludin B. Epidemiology of incomplete childhood immunization: an analysis of reported immunization status in outer western Sydney. J Paediatr Child Health. 1993;29:384-8. [pmid: 8240868].
45 Brimberry R. Vaccination of high-risk patients for influenza: a comparison of telephone and mail reminder methods. J Fam Pract. 1988;26:397-400. [pmid: 3282026].
46 Buchner DM, Larson EB, White RF. Influenza vaccination in community elderly: a controlled trial of postcard reminders. J Am Geriatr Soc. 1987;35:755-60. [pmid: 3301990].
47 Buffington J, Bell KM, LaForce FM. Target-based model for increasing influenza immunizations in private practice. J Gen Intern Med. 1991;6:204-9. [pmid: 2066823].
48 Campbell JR, Szilagyi PG, Rodewald LE, Doane C, Roughmann KJ. Patient-specific reminder letters and pediatric well-child-care show rates. Clin Pediatr. 1994;33(5):268-72.
49 Carter WB, Beach LR, Inui TS. Flu shot study: using multiattribute theory to design a vaccination intervention. Organizational Behavior and Human Decision Processes. 1986;38:378-91. [pmid: 10279492].
50 Centers for Disease Control and Prevention. Increasing influenza vaccination rates for Medicare beneficiaries-Montana and Wyoming, 1994. MMWR. 1995;44:744-46. [pmid: 7565555].
51 Ferson MJ, Fitzsimmons G, Christie D, Woollett H. School health nurse interventions to increase immunisation uptake in school entrants. Public Health. 1995;109:25-9. [pmid: 7871143].
52 Frame PS, Zimmer JG, Werth PL, Jackson Hall W, Eberly SW. Computer-based vs manual health maintenance tracking: a controlled study. Arch Fam Med. 1994;3:581-8. [pmid: 7921293].
53 Garr DR, Ornstein SM, Jenkins RG, Zemp LD. Effect of routine use of computer-generated preventive reminders in a clinical practice. Am J Prev Med. 1993;9:55-61. [pmid: 8439440].
54 Gerace TM, Sangster JF. Influenza vaccination: a comparison of two outreach strategies. Fam Med. 1988;20:43-5. [pmid: 3342961].
55 Grabenstein JD, Hartzema AG, Guess HA, Johnston WP. Community pharmacists as immunization advocates: a pharmacoepidemiologic experiment. International Journal of Pharmacy Practice. 1993;2:5-10.
56 Honkanen PO, Keistinen T, Kivel SL. Impact of vaccination strategy and methods of information on influenza and pneumococcal vaccination coverage in the elderly population. Vaccine. 1997;15:317-20. [pmid: 9139492].
57 Hutchison BG, Shannon HS. Effect of repeated annual reminder letters on influenza immunization among elderly patients. J Fam Pract. 1991;33:187-9. [pmid: 1890400].
58 Kouides RW, Lewis B, Bennett NM, et al. Performance-based incentive program for influenza immunization in the elderly. Am J Prev Med. 1993;9:250-5. [pmid: 8398226].
59 Larson EB, Bergman J, Heidrich F, Alvin BL, Schneeweiss R. Do postcard reminders improve influenza compliance?. A prospective trial of different postcard "cues." Med Care. 1982;20:639-48. [pmid: 7109747].
60 Leirer VO, Morrow DG, Pariante G, Doksum T. Increasing influenza vaccination adherence through voice mail. J Am Geriatr Soc. 1989;37:1147-50. [pmid: 2592722].
61 Lieu TA, Black SB, Ray P, et al. Computer-generated recall letters for underimmunized children: how cost-effective?. Pediatr Infect Dis J. 1997;16:28-33. [pmid: 9002097].
62 Mansoor OD. Ask and you shall be given: practice based immunisation coverage information. N Z Med J. 1993;106:504-5. [pmid: 8247435].
63 Margolis KL, Nichol KL, Wuorenma J, Von Sternberg TL. Exporting a successful influenza vaccination program from a teaching hospital to a community outpatient setting. J Am Geriatr Soc. 1992;40:1021-3. [pmid: 1401675].
64 McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135:991-7. [pmid: 3093045].
65 Moran WP, Nelson K, Wofford JL, Velez R, Case LD. Increasing influenza immunization among high-risk patients: education or financial incentive. Am J Med. 1996;101:612-20. [pmid: 9003108].
66 Moran WP, Wofford JL, Velez R. Assessment of influenza immunization of community elderly: illustrating the need for community level health information. Carolina Health Services Review. 1995;3:21-9.
67 Moran WP, Nelson K, Wofford JL, Velez R. Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med. 1992;7:535-7. [pmid: 1403212].
68 Mullooly JP. Increasing influenza vaccination among high-risk elderly: a randomized controlled trial of a mail cue in an HMO setting. Am J Public Health. 1987;77:626-7. [pmid: 3565663].
69 Murphy AW, Harrington M, Bury G, et al. Impact of a collaborative immunisation programme in an inner city practice. Ir Med J. 1996;89:220-1. [pmid: 8996951].
70 Newman CPStJ. Immunization in childhood and computer scheme participation. Public Health. 1983;97:208-13. [pmid: 6622641].
71 Nexøe J, Kragstrup J, Rønne T. Impact of postal invitations and user fee on influenza vaccination rates among the elderly: a randomized controlled trial in general practice. Scand J Prim Health Care. 1997;15:109-12. [pmid: 9232713].
72 Nichol KL, Korn JE, Margolis KL, Poland GA, Petzel RA, Lofgren RP. Achieving the national health objective for influenza immunization: success of an institution-wide vaccination program. Am J Med. 1990;89:156-60. [pmid: 2382664].
73 Nicholson KG, Wiselka MJ, May A. Influenza vaccination of the elderly: perceptions and policies of general practitioners and outcome of the 1985-86 immunization programme in Trent, UK. Vaccine. 1987;5:302-6. [pmid: 3433918].
74 Ornstein SM, Garr DR, Jenkins RG, Rust PF, Arnon A. Computer-generated physician and patient reminders: tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32:82-90. [pmid: 1985140].
75 Peterson L. Prevention and community compliance in immunization schedules. Prevention and Health: Directions for Policy and Practice. 1987;5:79-95.
76 Satterthwaite P. Randomized intervention study to examine the effect on immunization coverage of making influenza vaccine available at no cost. N Z Med J. 1997;110:58-60. [pmid: 9076288].
77 Siebers MJ, Hunt VB. Increasing the pneumococcal vaccination rate of elderly patients in a general internal medicine clinic. J Am Geriatr Soc. 1985;33:175-8. [pmid: 3973336].
78 Soljak MA, Handford S. Early results from the Northland immunisation register. N Z Med J. 1987;100:244-6. [pmid: 3454893].
79 Spaulding SA, Kugler JP. Influenza immunization: the impact of notifying patients of high-risk status. J Fam Pract. 1991;33:495-8. [pmid: 1940817].
80 Stehr-Green PA, Dini EF, Lindegren ML, Patriarca PA. Evaluation of telephoned computer-generated reminders to improve immunization coverage at inner-city clinics. Public Health Rep. 1993;108:426-30. [pmid: 8341774].
81 Thompson RS. 2. What have HMOs learned about clinical prevention services? An examination of the experience at Group Health Cooperative of Puget Sound. Milbank Q. 1996;74:469-509. [pmid: 8941259].
82 Tollestrup K, Hubbard BB. Evaluation of a follow-up system in a county health department's immunization clinic. Am J Prev Med. 1991;7:24-8. [pmid: 1907834].
83 Tucker JB, DeSimone JP. Patient response to mail cues recommending influenza vaccine. Fam Med. 1987;19:209-12. [pmid: 3596114].
84 Yokley JM, Glenwick DS. Increasing the immunization of preschool children: an evaluation of applied community interventions. J Appl Behav Anal. 1984;17:313-25. [pmid: 6439714].
85 Young SA, Halpin TJ, Johnson DA, Irvin JJ, Marks JS. Effectiveness of a mailed reminder on the immunization levels of infants at high risk of failure to complete immunizations. Am J Public Health. 1980;70:422-4. [pmid: 7361966].
86 Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
87 Carter H, Jones IG. Measles immunisation: results of a local programme to increase vaccine uptake. BMJ. 1985;290:1717-9. [pmid: 3924229].
88 Frank JW, Henderson M, McMurray L. Influenza vaccination in the elderly: 1. determinants of acceptance. CMAJ. 1985;132:371-5. [pmid: 3971253].
89 Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
90 McDowell I, Newell C, Rosser W. Follow-up study of patients advised to obtain influenza immunizations. Fam Med. 1990;22:303-6. [pmid: 2384206].
91 Nichol KL. Long-term success with the national health objective for influenza vaccination: an institution-wide model. J Gen Intern Med. 1992;7:595-600. [pmid: 1453242].
92 Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 1991;145:807-14. [pmid: 1913409].
93 Rosser WW, Hutchison BG, McDowell I, Newell C. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146:911-17. [pmid: 1544078].
94 Thompson RS, Taplin SH, McAfee TA, Mandelson MT, Smith AE. Primary and secondary prevention services in clinical practice: twenty years' experience in development, implementation, and evaluation. JAMA. 1995;273:1130-5. [pmid: 7707602].
95 Frank JW, McMurray L, Henderson M. Influenza vaccination in the elderly: 2. the economics of sending reminder letters. CMAJ. 1985;132:516-21. [pmid: 3971268].
96 Grabenstein JD, Hartzema AG, Guess HA, Johnston WP, Rittenhouse BE. Community pharmacists as immunization advocates. Cost-effectiveness of a cue to influenza vaccination. Med Care. 1992;30:503-13. [pmid: 1593916].
97 Lieu TA, Capra AM, Makol J, Black SB, Shinefield HR. Effectiveness and cost-effectiveness of letters, automated telephone messages, or both for underimmunized children in a health maintenance organization. Pediatrics. 1998;101. [pmid: 9521970].
98 McLeod D, Bowie RD, Kljakovic M. Cost of childhood immunization in general practice. N Z Med J. 1998;111:73-6. [pmid: 9549556].
99 Bennett NM, Lewis B, Doniger AS, et al. Coordinated, communitywide program in Monroe County, New York, to increase influenza immunization rates in the elderly. Arch Intern Med. 1994;154:1741-5. [pmid: 8042891].
100 Bloom HG, Bloom JS, Krasnoff L, Frank AD. Increased utilization of influenza and pneumococcal vaccines in an elderly hospitalized population. J Am Geriatr Soc. 1988;36:897-901. [pmid: 3171029].
101 Broussard LA, Blankenship FB. Shots for tots: Louisiana's infant immunization initiative. Journal of the Society of Pediatric Nurses. 1996;1:113-6. [pmid: 8987019].
102 Brownlee HJ, Brown DL, D'Angelo RJ. Utilization of pneumococcal vaccine in a family practice residency. J Fam Pract. 1982;15:1111-4. [pmid: 7142929].
103 Campbell JF, Donohoe MA, Nevin-Woods C, et al. Hawaii pneumococcal disease initiative. Am J Public Health. 1993;83:1175-6. [pmid: 8342733].
104 Cates CJ. Handout about tetanus immunisation: influence on immunisation rate in general practice. BMJ. 1990;300:789-90. [pmid: 2322743].
105 Centers for Disease Control and Prevention. National coalition for adult immunization: activities to increase influenza vaccination levels, 1989-1991. MMWR. 1992;41:772-5. [pmid: 1406569].
106 Elangovan S, Kallail KJ, Vargo G. Improving pneumococcal vaccination rates in an elderly population by patient education in an outpatient clinic. J Am Board Fam Pract. 1996;9:411-3. [pmid: 8923398].
107 Elster AB, Lamb ME, Tavare J, Ralston CW. Medical and psychosocial impact of comprehensive care on adolescent pregnancy and parenthood. JAMA. 1987;258:1187-92. [pmid: 3626002].
108 Etkind P, Simon M, Shannon S, et al. Impact of the Medicare Influenza Demonstration Project on influenza vaccination in a county in Massachusetts, 1988-1992. J Community Health. 1996;21:199-209. [pmid: 8726210].
109 Hand JS, Anderson D, Feffer D, Day CA. Successful school immunization program - or not?. J Sch Health. 1980;50. [pmid: 6897996].
110 Knoell KR, Leeds AL. Influenza vaccination program for elderly outpatients. American Journal of Hospital Pharmacy. 1991;48:256-9. [pmid: 2003497].
111 Macdonald H, Roder D. Planning, implementation and evaluation of an immunization promotion campaign in South Australia. Hygiene. 1985;4:13-7.
112 Madlon-Kay DJ. Improving the periodic health examination: use of a screening flow chart for patients and physicians. J Fam Pract. 1987;25:470-3. [pmid: 3681206].
113 Ratner ER, Fedson DS. Influenza and pneumococcal immunization in medical clinics, 1978-1980. Arch Intern Med. 1983;143:2066-9. [pmid: 6639226].
114 Turner BJ, Day SC, Borenstein B. Controlled trial to improve delivery of preventive care: physician or patient reminders. J Gen Intern Med. 1989;4:403-9. [pmid: 2677271].
115 Williams DM, Daugherty LM, Aycock DG, Lindley CM, Harris MJ. Effectiveness of improved targeting efforts for influenza immunization in an ambulatory care setting. Hospital Pharmacy. 1987;22:462-4. [pmid: 10282251].
116 Centers for Disease Control and Prevention. Pneumococcal immunization program-California, 1986-1988. MMWR. 1989;38:517-9. [pmid: 2501645].
117 Dickey LL, Petitti D. Patient-held minirecord to promote adult preventive care. J Fam Pract. 1992;34:457-63. [pmid: 1556540].
118 Herman CJ, Speroff T, Cebul RD. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. 1994;42:1154-9. [pmid: 7963201].
119 Rodriguez RM, Baraff LJ. Emergency department immunization of the elderly with pneumococcal and influenza vaccines. Ann Emerg Med. 1993;22:1729-32. [pmid: 8214864].
120 Westman S, Halbert RJ, Walton LG, Henneman CE. A "clinic without walls": the Los Angeles Immunization Demonstration Project. Am J Public Health. 1997;87:293-4. [pmid: 9103117].
121 Baughman AL, Williams WW, Atkinson WL, Cook LG, Collins M. Impact of college prematriculation immunization requirements on risk for measles outbreaks. JAMA. 1994;272:1127-32. [pmid: 7933326].
122 Carlson JAK, Lewis CA. Effect of the immunization program in Ontario schools. CMAJ. 1985;133:215-6. [pmid: 4016629].
123 Chaiken BP, Williams NM, Preblud SR, Parkin W, Altman R. Effect of a school entry law on mumps activity in a school district. JAMA. 1987;257:2455-8. [pmid: 3573244].
124 Nelson DB, Layde MM, Chatton TB. Rubella susceptibility in inner-city adolescents: the effect of a school immunization law. Am J Public Health. 1982;72:710-3. [pmid: 7091461].
125 Robbins KB, Brandling-Bennett AD, Hinman AR. Low measles incidence: association with enforcement of school immunization laws. Am J Public Health. 1981;71:270-4. [pmid: 7468859].
126 Scheiber M, Halfon N. Immunizing California's children: effects of current policies on immunization levels. West J Med. 1990;153:400-5. [pmid: 2244375].
127 Schulte EE, Birkhead GS, Kondracki SF, Morse DL. Patterns of Haemophilus influenzae type b invasive disease in New York state, 1987 to 1991: the role of vaccination requirements for day-care attendance. Pediatrics. 1994;94 (6 Pt 2):1014-6. [pmid: 7971041].
128 van Loon FPL, Holmes SJ, Sirotkin BI, et al. Mumps surveillance-United States, 1988-1993. In: CDC Surveillance Summaries, August 11,1995. MMWR. 1995;44(No. SS-3):1-14.
129 Centers for Disease Control and Prevention. School immunization requirements for measles-United States, 1981. MMWR. 1981;30:158-60. [pmid: 6789068].
130 Comparison of measles experience in Ottawa, Ontario and Hull, Quebec. Canada Diseases Weekly Report 1990;16(24):111-3.
131 Schum TR, Nelson DB, Duma MA, Sedmak GV. Increasing rubella seronegativity despite a compulsory school law. Am J Public Health. 1990;80:66-9. [pmid: 2293805].
132 Expanded programme on immunization; sentinel school surveillance programme for immunization status and vaccine-preventable diseases. Wkly Epidemiol Rec 1992;67:268-70.
133 Centers for Disease Control and Prevention. Increasing pneumococcal vaccination rates among patients of a national health-care alliance-United States, 1993. JAMA. 1995;274:1333-4. [pmid: 7563545].
134 Mukherji PS, Ryan MP, Howie JGR, Stevenson JSK. Consultation behaviour and the influence of the media. Journal of the Royal College of General Practitioners. 1982;32:242-4. [pmid: 7086758].
135 Clayton EW, Hickson GB, Miller CS. Parents' responses to vaccine information pamphlets. Pediatrics. 1994;93:369-72. [pmid: 8115193].
136 Esernio-Jenssen D, Turow V. Parents' understanding of the CDC's vaccine information material [letter]. Am J Public Health. 1996;86:1648-9. [pmid: 8916537].
137 Henry RL, Adler JA. Missed immunization-are doctors to blame?. Med J Aust. 1988;148. [pmid: 3340055].
138 Lieu TA, Glauber JH, Fuentes-Afflick E, Lo B. Effects of vaccine information pamphlets on parents' attitudes. Arch Pediatr Adolesc Med. 1994;148:921-5. [pmid: 8075734].
139 Belcher DW. Implementing preventive services: success and failure in an outpatient trial. Arch Intern Med. 1990;150:2533-41. [pmid: 2244769].
140 Dietrich AJ, Duhamel M. Improving geriatric preventive care through a patient-held checklist. Fam Med. 1989;21:195-8. [pmid: 2744287].
141 Klachko DM, Wright DL, Gardner DW. Effect of a microcomputer-based registry on adult immunizations. J Fam Pract. 1989;29:169-72. [pmid: 2754405].
142 McCormick MC, Shapiro S, Starfield BH. Association of patient-held records and completion of immunizations. Clin Pediatr. 1981;20:270-4.
143 Turner RC, Waivers LE, O'Brien K. Effect of patient-carried reminder cards on the performance of health maintenance measures. Arch Intern Med. 1990;150:645-7. [pmid: 2310284].
144 Cutts FT, Orenstein WA, Bernier RH. Causes of low preschool immunization coverage in the United States [review]. Annu Rev Public Health. 1992;13:385-98. [pmid: 1599595].
145 Arnold PJ, Schlenker TL. Impact of health care financing on childhood immunization practices. American Journal of Diseases of Children. 1992;146:728-32. [pmid: 1595629].
146 Bennett NM, Lewis B, Doniger AS, et al. Coordinated, communitywide program in Monroe County, New York, to increase influenza immunization rates in the elderly. Arch Intern Med. 1994;154:1741-5. [pmid: 8042891].
147 Combs SP, Walter EB, Drucker RP, Clements DA. Removing a major barrier to universal hepatitis B immunization in infants. Arch Pediatr Adolesc Med. 1996;150:112-4. [pmid: 8541998].
148 Hutchins SS, Rosenthal J, Eason P, et al. Effectiveness and cost-effectiveness of linking the special supplemental program for women, infants and children (WIC) and immunization activities, 1997. American Journal of Public Health Policy 1999;20(4). In press.
149 Ives DG, Lave JR, Traven ND, Kuller LH. Impact of Medicare reimbursement on influenza vaccination rates in the elderly. Prev Med. 1994;23:134-41. [pmid: 8047518].
150 Lurie N, Manning WG, Peterson C, Goldberg GA, Phelps CA, Lillard L. Preventive care: do we practice what we preach?. Am J Public Health. 1987;77:801-4. [pmid: 3592032].
151 Mainous AG III, Hueston WJ. Medicaid free distribution programs and availability of childhood immunizations in rural practices. Fam Med. 1995;27:166-9. [pmid: 7774774].
152 Merkel PA, Caputo GC. Evaluation of a simple office-based strategy for increasing influenza vaccine administration and the effect of differing reimbursement plans on the patient acceptance rate. J Gen Intern Med. 1994;9:679-83. [pmid: 7876950].
153 Rodewald LE, Szilagyi PG, Holl J, Shone LR, Zwanziger J, Raubertas RF. Health Insurance for low-income, working families: impact on the delivery of immunizations to preschool children. Arch Pediatr Adolesc Med. 1997;151:798-803. [pmid: 9265881].
154 Ruch-Ross HS, O'Connor KG. Immunization referral practices of pediatricians in the United States. Pediatrics. 1994;94:508-12. [pmid: 7936861].
155 Scarbrough ML, Landis SE. Pilot study for the development of a hospital-based immunization program. Clinical Nurse Specialist. 1997;11:70-5. [pmid: 9233146].
156 Szilagyi PG, Rodewald LE, Humiston SG, et al. Effect of 2 urban emergency department immunization programs on childhood immunization rates. Arch Pediatr Adolesc Med. 1997;151:999-1006. [pmid: 9343010].
157 Taylor JA, Darden PM, Slora E, Hasemeier CM, Asmussen L, Wasserman R. Influence of provider behavior, parental characteristics, and a public policy initiative on the immunization status of children followed by private pediatricians: a study from pediatric research in office settings. Pediatrics. 1997;99:209-15. [pmid: 9024448].
158 Zimmerman RK, Janosky JE. Immunization barriers in Minnesota private practices: the influence of economics and training on vaccine timing. Family Practice Research Journal. 1993;13:213-24. [pmid: 8296585].
159 Zimmerman RK, Medsger AR, Ricci EM, Raymund M, Mieczkowski TA, Grufferman S. Impact of free vaccine and insurance status on physician referral of children to public vaccine clinics. JAMA. 1997;278:996-1000. [pmid: 9307347].
160 Hueston WJ, Mainous AG III, Farrell JB. Childhood immunization availability in primary care practices: effects of programs providing free vaccines to physicians. Arch Fam Med. 1994;3:605-9. [pmid: 7921296].
161 Lave JR, Ives DG, Traven ND, Kuller LH. Evaluation of a health promotion demonstration program for the rural elderly. Health Serv Res. 1996;31:261-81. [pmid: 8698585].
162 Nichol KL. Improving influenza vaccination rates for high-risk inpatients. Am J Med. 1991;91:584-8. [pmid: 1750427].
163 Polis MA, Davey VJ, Collins ED, Smith JP, Rosenthal RE, Kaslow RA. Emergency department as part of a successful strategy for increasing adult immunization. Ann Emerg Med. 1988;17:1016-8. [pmid: 3177987].
164 Rodewald LE, Szilagyi PG, Humiston SG, et al. Effect of emergency department immunizations on immunization rates and subsequent primary care visits. Arch Pediatr Adolesc Med. 1996;150:1271-6. [pmid: 8953999].
165 Birkhead GS, LeBaron CW, Parsons P, et al. Immunization of children enrolled in the Special Supplemental Food Program for Women, Infants, and Children (WIC): the impact of different strategies. JAMA. 1995;274:312-6. [pmid: 7609260].
166 Golden RE Evaluation of three immunization interventions among families participating in the Special Supplemental Nutrition Program for Women, Infants, and Children in South Central and South East Los Angeles [dissertation]. Los Angeles, CA: University of California 1997.
167 Guerra FA, Gonzalez H F, Woehler KS, Pruski C, and Pfeil D. San Antonio age-appropriate immunization demonstration project. In: Proceedings of the 27th National WIC/Immunization Conference, Washington, DC: U.S. Department of Health and Human Services, 1993:61-5.
168 Hoekstra E, Megaloeconomou Y, Guerrero H, Johnson-Partlow T, Mize J, Devier JR. Citywide implementation of WIC/immunization linkage in Chicago [abstract]. Presented at the 31st National Immunization Conference, Atlanta, GA, May 19-22, 1997.
169 Lazorik D, Larzelere M. Improvement in immunization levels following enhanced immunization activities at WIC sites in Massachusetts [abstract]. Presented at the 31st National Immunization Conference, Atlanta, GA, May 19-22, 1997.
170 Needham D. Effect of WIC/immunization coordination on immunization coverage levels [abstract]. Presented at the 31 National Immunization Conference, Atlanta, GA, May 19-22, 1997.
171 Stevenson J, Dietz V, Dini G, et al. Working with the Women, Infants, and Children program (WIC) to raise vaccination coverage levels in Georgia's public health clinics [abstract]. Presented at the 30th National Immunization Conference, Washington, DC, April 9-12, 1996.
172 Watson JC, Flatt K, Rosenthal J, Anderson K. Improving vaccination coverage among children in the WIC supplemental food program, Dallas, 1992-94. In: Abstracts of the 123rd annual meeting and exposition of the American Public Health Association, Dallas, TX, October 1995. Washington, DC: American Public Health Association 1995.
173 Flatt K, Watson JC, Anderson KN, Logan L, and Nguyen VA. Cost comparison of methods used to increase immunization levels at a WIC setting. In: Abstracts of the 124th annual meeting and exposition of the American Public Health Association, New York, NY, November 17-21, 1996. Washington, DC: American Public Health Association, 1996: Session 3299.
174 Begg NT, White JM. Survey of pre-school vaccination programmes in England and Wales. Community Medicine. 1988;10:344-50. [pmid: 3233915].
175 Black ME, Ploeg J, Walter SD, Hutchinson BG, Scott EAF, Chambers LW. Impact of a public health nurse intervention on influenza vaccine acceptance. Am J Public Health. 1993;83:1751-3. [pmid: 8259810].
176 Bond LM, Nolan TM, Lester RA. Home vaccination for children behind in their immunisation schedule: a randomised controlled trial. Med J Aust. 1998;168:487-90. [pmid: 9631672].
177 Clark J, Day J, Howe E, Williams P, Biley A. Developing an immunisation protocol for the primary health care team. Health Visitor. 1995;68:196-8. [pmid: 7751149].
178 Crittenden P, Rao M. Immunisation coordinator: improving uptake of childhood immunisation [review]. Commun Dis Rep. 1994;4:R79-R81.
179 Jefferson N, Sleight G, Macfarlane A. Immunisation of children by a nurse without a doctor present. BMJ. 1987;294:423-4. [pmid: 3101907].
180 McKeith D. Parents attitudes to measles immunization [letter]. Journal of the Royal College of General Practitioners. 1987;37. [pmid: 3694581].
181 Moore BJ, Morris DW, Burton B, Kilcrease DT. Measuring effectiveness of service aides in infant immunization surveillance program in North Central Texas. Am J Public Health. 1981;71:634-6. [pmid: 7235103].
182 Rodewald LE, Szilagyi PG, Humiston SG, Barth R, Kraus R, Raubertas RF. Randomized study of tracking with outreach and provider prompting to improve immunization coverage and primary care. Pediatrics. 1999;103:31-8. [pmid: 9917436].
183 Rosenberg Z, Findley S, McPhillips S, Penachio M , Silver P. Community-based strategies for immunizing the "hard-to-reach" child: the New York State immunization and primary health care initiative. Am J Prev Med. 1995;11 (suppl 1):14-20. [pmid: 7669356].
184 Salmond CE, Soljak MA, Bandaranayake DR, Stehr-Green P. Impact of a promotion program for hepatitis B immunisation. Aust J Public Health. 1994;18:253-7. [pmid: 7841252].
185 While AE. Health visitor contribution to pre-school child prophylaxis. Public Health. 1987;101:229-32. [pmid: 3659236].
186 Wood D, Halfon N, Donald-Sherbourne C, et al. Increasing immunization rates among inner-city, African American children: a randomized trial of case management. JAMA. 1998;279:29-34. [pmid: 9424040].
187 Jones AE. Domiciliary immunisation for preschool child defaulters. BMJ. 1984;289:1429-31. [pmid: 6437585].
188 Kominski R, Adams A. Social and economic characteristics of students, October, 1991 (P20). Washington, D.C.: U.S. Department of Commerce, Bureau of the Census. Current Population Reports Series 1991.
189 Unti LM, Coyle KK, Woodruff BA, Boyer-Chuanroong L. Incentives and motivators in school-based hepatitis B vaccination programs. J Sch Health. 1997;67:265-8. [pmid: 9358379].
190 Lopez J, DiLiberto J, McGuckin M. Infection control in day-care centers: present and future needs. Am J Infect Control. 1988;16:26-9. [pmid: 3369745].
191 O'Mara LM, Isaacs S. Evaluation of registered nurses follow-up on the reported immunization status of children attending child care centres. Can J Public Health. 1993;84:124-7. [pmid: 8334605].
192 Bell LM, Pritchard M, Anderko R, Levenson R. Program to immunize hospitalized preschool-aged children: evaluation and impact. Pediatrics. 1997;100:192-6. [pmid: 9240798].
193 Brink SG. Provider reminders: changing information format to increase infant immunizations. Med Care. 1989;27:648-53. [pmid: 2725091].
194 Carlin E, Carlson R, Nordin J. Using continuous quality improvement tools to improve pediatric immunization rates. Jt Comm J Qual Improv. 1996;22:277-88. [pmid: 8829706].
195 Chambers CV, Balaban DJ, Carlson BL, Grasberger DM. Effect of microcomputer-generated reminders on influenza vaccination rates in a university-based family practice center. J Am Board Fam Pract. 1991;4:19-26. [pmid: 1996510].
196 Cheney C, Ramsdell JW. Effect of medical records' checklists on implementation of periodic health measures. Am J Med. 1987;83:129-36. [pmid: 3605164].
197 Chodroff CH. Cancer screening and immunization quality assurance using a personal computer. Quality Review Bulletin. 1990;16:279-87. [pmid: 2122353].
198 Clancy CM, Gelfman D, Poses RM. Strategy to improve the utilization of pneumococcal vaccine. J Gen Intern Med. 1992;7:14-8. [pmid: 1548543].
199 Cohen DI, Littenberg B, Wetzel C, Neuhauser D. Improving physician compliance with preventive medicine guidelines. Med Care. 1982;20:1040-5. [pmid: 7132464].
200 Crouse BJ, Nichol K, Peterson DC, Grimm MB. Hospital-based strategies for improving influenza vaccination rates. J Fam Pract. 1994;38:258-61. [pmid: 8126406].
201 Gelfman DM, Witherspoon JM, Buchsbaum DG, Centor RM. Short-term results of an immunization compliance program. Virginia Medical. 1986;113:532-4. [pmid: 3776344].
202 Gill JM, Fisher JA. Improving childhood immunizations in a family practice office. Del Med J. 1997;69:13-9. [pmid: 9018921].
203 Hahn DL, Berger MG. Implementation of a systematic health maintenance protocol in a private practice. J Fam Pract. 1990;31:492-504. [pmid: 2230674].
204 Harper PG, Murray DM. Organizational strategy to improve adolescent measles-mumps-rubella vaccination in a low socioeconomic population: a method to reduce missed opportunities. Arch Fam Med. 1994;3:257-62. [pmid: 8180716].
205 Harper PG, Madlon-Kay DJ, Luxenberg MG, Tempest R. Clinic system to improve preschool vaccinations in a low socioeconomic status population. Arch Pediatr Adolesc Med. 1997;151:1220-3. [pmid: 9412597].
206 Harris RP, O'Malley MS, Fletcher SW, Knight BP. Prompting physicians for preventive procedures: a five-year study of manual and computer reminders. Am J Prev Med. 1990;6:145-52. [pmid: 2397138].
207 Hutchison BG. Effect of computer-generated nurse/physician reminders on influenza immunization among seniors. Fam Med. 1989;21:433-7. [pmid: 2612799].
208 Klein RS, Adachi N. Pneumococcal vaccine in the hospital: improved use and implications for high-risk patients. Arch Intern Med. 1983;143:1878-81. [pmid: 6354122].
209 Korn JE, Schlossberg LA, Rich EC. Improved preventive care following an intervention during an ambulatory care rotation: carryover to a second setting. J Gen Intern Med. 1988;3:156-60. [pmid: 3357072].
210 Loeser H, Zvagulis I, Hercz L, Pless IB. Organization and evaluation of a computer-assisted, centralized immunization registry. Am J Public Health. 1983;73:1298-301. [pmid: 6625035].
211 Mandel I, Franks P, Dickinson J. Improving physician compliance with preventive medicine guidelines. J Fam Pract. 1985;21:223-4. [pmid: 2993472].
212 McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record: a two-year randomized trial. Ann Intern Med. 1984;100:130-8. [pmid: 6691639].
213 Payne TH, Galvin M, Taplin SH, Austin B, Savarino J, Wagner EH. Practicing population-based care in an HMO: evaluation after 18 months. HMO Practice. 1995;9:101-6. [pmid: 10151092].
214 Ravet J. Opportunistic recall-a plateau [letter]. Med J Aust. 1988;148. [pmid: 3340052].
215 Reading R, Colver A, Openshaw S, Jarvis S. Do interventions that improve immunisation uptake also reduce social inequalities in uptake?. BMJ. 1994;308:1142-4. [pmid: 8173457].
216 Rodney WM, Chopivsky P, Quan M. Adult immunization: the medical record design as a facilitator for physician compliance. Journal of Medical Education. 1983;58:576-80. [pmid: 6864746].
217 Setia U, Serventi I, Lorenz P. Factors affecting the use of influenza vaccine in the institutionalized elderly. J Am Geriatr Soc. 1985;33:856-8. [pmid: 4067169].
218 Shank JC, Powell T, Llewelyn J. Five-year demonstration project associated with improvement in physician health maintenance behavior. Fam Med. 1989;21:273-8. [pmid: 2753254].
219 Shreiner DT, Petrusa ER, Rettie CS, Kluge RM. Improving compliance with preventive medicine procedures in a house staff training program. South Med J. 1988;81:1553-7. [pmid: 3201302].
220 Stets K, Harper P, Christensen R. Immunization audits and protocols: valuable tools to improve rates. Minn Med. 1996;79:43-5. [pmid: 8772317].
221 Szilagyi PG, Rodewald LE, Humiston SG, et al. Reducing missed opportunities for immunizations: easier said than done. Arch Pediatr Adolesc Med. 1996;150:1193-200. [pmid: 8904862].
222 Tape TG, Givner N, Wigton RS. Process in ambulatory care: a controlled clinical trial of computerized records. Symposium on Computer Applications in Medical Care 1988;749-52. Need to verify all.
223 Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care: effects on physician compliance. Med Care. 1986;24:659-66. [pmid: 3736141].
224 Tobacman JK. Increased use of pneumococcal vaccination in a medicine clinic following initiation of a quality assessment monitor. Infect Control Hosp Epidemiol. 1992;13:144-6. [pmid: 1564311].
225 Weingarten MA, Bazel D, Shannon HS. Computerized protocol for preventive medicine: a controlled self-audit in family practice. Fam Pract. 1989;6:120-4. [pmid: 2744295].
226 Davidson RA, Fletcher SW, Retchin S, Duh S. Nurse-initiated reminder system for the periodic health examination: implementation and evaluation. Arch Intern Med. 1984;144:2167-70. [pmid: 6333855].
227 McDonald CJ, Hui SL, Tierney WM. Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput. 1992;9:304-12. [pmid: 1522792].
228 Ravet J. Tetanus immunization [letter]. Med J Aust. 1987;146. [pmid: 3574199].
229 Rodney WM, Johnson RA, Beaber RJ, Jonokuchi C, Kujubu D. Residency chart review: preventive medicine practice as noted in the medical record. Family Practice Research Journal. 1982;1:140-51.
230 Carey TS, Levis D, Pickard CG, Bernstein J. Development of a model quality-of-care assessment program for adult preventive care in rural medical practices. Quality Review Bulletin. 1991;17:54-9. [pmid: 2034441].
231 Colver AF. Health surveillance of preschool children: four years experience. BMJ. 1990;300:1246-8. [pmid: 1693864].
232 Fleming DM, Lawrence MSTA. Impact of audit on preventive measures. BMJ. 1983;287:1852-4. [pmid: 6423043].
233 Kelly SD. Impact of a microcomputer on a general practice immunization clinic. Practitioner. 1988;232:197-201. [pmid: 3186604].
234 Kern DE, Harris WL, Boekeloo BO. Use of an outpatient medical record audit to achieve educational objectives: changes in residents' performances over six years. J Gen Intern Med. 1990;5:218-24. [pmid: 2341921].
235 LeBaron CW, Chaney M, Baughman AL, et al. Impact of measurement and feedback on vaccination coverage in public clinics, 1988-1994. JAMA. 1997;277:631-5. [pmid: 9039880].
236 Lynch ML. Uptake of childhood immunization and financial incentives to general practitioners. Health Econ. 1994;3:117-25. [pmid: 8044212].
237 Morrow RW, Gooding AD, Clark C. Improving physicians' preventive health care behavior through peer review and financial incentives. Archives of Family Medicine. 1995;4:165-9. [pmid: 7842155].
238 Ritchie LD, Bisset AF, Russell D, Leslie V, Thomson I. Primary and preschool immunisation in Grampian: progress and the 1990 contract. BMJ. 1992;304:816-9. [pmid: 1392710].
239 Dini EF, Chaney M, Moolenaar RL, LeBaron CW. Information as intervention: how Georgia used vaccination coverage data to double public sector vaccination coverage in seven years. Journal of Public Health Management Practice. 1996;2:45-9.
240 Christy C, McConnochie KM, Zernik N, Brzoza S. Impact of an algorithm-guided nurse intervention on the use of immunization opportunities. Arch Pediatr Adolesc Med. 1997;151:384-91. [pmid: 9111438].
241 Fedson DS, Kessler HA. Hospital-based influenza immunization program, 1977-78. Am J Public Health. 1983;73:442-5. [pmid: 6829828].
242 Hoey JR, McCallum HP, Lepage EM. Expanding the nurse's role to improve preventive service in an outpatient clinic. CMAJ. 1982;127:27-8. [pmid: 7083107].
243 Klein RS, Adachi N. Effective hospital-based pneumococcal immunization program. Arch Intern Med. 1986;146:327-9. [pmid: 3947193].
244 Margolis KL, Lofgren RP, Korn JE. Organizational strategies to improve influenza vaccine delivery: a standing order in a general medicine clinic. Arch Intern Med. 1988;148:2205-7. [pmid: 3178378].
245 Morton MR, Spruill WJ, Cooper JW. Pharmacist impact on pneumococcal vaccination rates in long-term-care facilities [letter]. American Journal of Hospital Pharmacy. 1988;45. [pmid: 3126652].
246 Nichol KL, Grimm MB, Peterson DC. Immunizations in long-term care facilities: policies and practice. J Am Geriatr Soc. 1996;44:349-55. [pmid: 8636576].
247 Landis S, Scarbrough ML. Using a vaccine manager to enhance in-hospital vaccine administration. J Fam Pract. 1995;41:364-9. [pmid: 7561710].
248 Bannerman B, Schram K. Influenza immunization program in long term care facilities. Canadian Journal of Infection Control. 1992;7:13-5. [pmid: 1525380].
249 Cowan JA, Heckerling PS, Parker JB. Effect of a fact sheet reminder on performance of the periodic health examination: a randomized controlled trial. Am J Prev Med. 1992;8:104-9. [pmid: 1599717].
250 Freed GL, Bordley WC, Clark SJ, Konrad TR. Universal hepatitis B immunization of infants: reactions of pediatricians and family physicians over time. Pediatrics. 1994;93:747-51. [pmid: 8165072].
251 Zimmerman RK, Barker WH, Strikas RA, et al. Developing curricula to promote preventive medicine skills: the Teaching Immunization for Medical Education (TIME) Project. JAMA. 1997;278:705-11. [pmid: 9286828].

### Appendix A Methods

In the Guide to Community Preventive Services; Systematic Reviews and Evidence-Based Recommendations, evidence is summarized regarding (a) the effectiveness of interventions; (b) the applicability of effectiveness data (i.e., the extent to which available effectiveness data might apply to other populations and settings); (c) other positive or negative effects of the intervention, including positive or negative health and nonhealth outcomes; (d) economic consequences; and (e) barriers to implementation of interventions. The process that was used to systematically review evidence and then translate that evidence into recommendations made in this chapter involved -

- forming a chapter development team;
- developing a conceptual approach to organizing, grouping, and selecting interventions;
- selecting interventions to evaluate;
- searching for and retrieving evidence;
- assessing the quality and summarizing the body of evidence of effectiveness;
- translating the body of evidence of effectiveness into recommendations;
- considering data on other issues; and
- identifying and summarizing research gaps.

This appendix summarizes how these methods were used in developing this chapter. The Guide's methods for systematic reviews and linking evidence to recommendations are explained in detail elsewhere (Task Force on Community Preventive Services, Manuscript in Preparations, 1999).

#### Chapter Development Team

This Guide chapter was developed by a multidisciplinary team representing a variety of perspectives. Contributors to this chapter are listed at the front of this chapter.

#### Conceptual Approach

The conceptual approach is described in this chapter text, beginning on page 2.

#### Search for Evidence

For each intervention reviewed, the team developed an analytic framework indicating possible links between the intervention under study and certain outcomes. The primary outcome of interest was always vaccination, but information regarding vaccine-preventable disease outcomes was also obtained, if available. Other outcomes were evaluated when thought to be relevant to a particular intervention (e.g., knowledge and attitudes for educational interventions and dropout rates for WIC [Special Supplemental Nutrition Program for Women, Infants, and Children] interventions). Electronic searches for literature were conducted of MEDLINE, Embase, Psychlit, CAB Health, and Sociological Abstracts. The team also reviewed reference lists in articles and consulted with immunization experts. To be included in the review, a study had to -

- have a publication date of 1980-1997;
- address universally recommended adult, adolescent, or childhood vaccinations;
- be a primary study rather than, for example, a guideline or review;
- take place in an industrialized country or countries;
- be written in English;
- met the chapter development team's definition of the interventions;
- provide information on one or more outcomes related to the analytic frameworks; and
- compare a group of persons who had been exposed to the intervention with a group who had not been exposed or who had been less exposed.

Studies were also reviewed that did not meet these criteria but had been recommended by one or more experts as having potential to change a preliminary assessment of effectiveness. For example, unpublished studies of interventions [These should not be listed in the references.] involving WIC and 1998 publications on home visits were reviewed.

##### Assessing the Quality and Summarizing the Body of Evidence of Effectiveness

Each study meeting the inclusion criteria was read by two reviewers who used a standardized abstraction form to record -

- information regarding the intervention being studied;
- the context in which the study was done (e.g., population or setting);
- descriptions of the evaluation and results; and
- an assessment of how well the study was executed.

Any disagreements between two reviewers were reconciled by consensus among the chapter development team members during the process of summarizing results into evidence tables (Appendix B). We used information from a variety of study designs to assess effectiveness, resulting in the following categories:

Suitability of Study Design for Assessing Effectiveness | Attributes
Greatest | Concurrent comparison groups and prospective measurement of exposure and outcome
Moderate | All retrospective designs or multiple pre- or postmeasurements but no concurrent comparison group
Least | Single pre- and postmeasurements and no concurrent comparison group or exposure and outcome measured in a single group at the same time

For two interventions where the literature was most extensive (provider reminder/recall and client reminder/recall), we excluded studies with least-suitable designs. Studies that did not make a concurrent or before/after comparison were never included.

Eight quality criteria were used to identify limitations in study execution -

- definition and selection of study and comparison population(s);
- definition and measurement of exposure and intervention;
- assessment of outcomes;
- follow-up and completion rates;
- bias;
- data analysis;
- confounding; and
- miscellaneous criteria (e.g., lack of statistical power).

Execution of each study was characterized as good, fair, or limited based on the total number of categories with limitations. Good studies had zero or one limitation; fair studies, two to four; and limited studies, five or more. Studies with serious problems in quality of execution (i.e., "limited" execution) did not qualify for the review. To summarize the findings on the effectiveness of an intervention across multiple studies, we displayed results of individual studies in tables and figures and reported median and range of provided effect measures.

We abstracted information from the studies regarding one or more outcomes of interest:

- measures of vaccination (i.e., vaccination coverage or doses delivered);
- disease outcomes, when available; and
- other outcomes (e.g., knowledge or attitudes for educational interventions), if available and relevant.

We represented results of each study as point estimates for change in vaccination coverage attributable to the interventions. We then calculated changes and baselines using the following formula:

- For studies with before/after measurements and concurrent comparison groups, (Ipost-Ipre) - (Cpost-Cpre); baseline = Ipre
- For studies with post-only coverage measurements and concurrent comparison groups, Ipost - Cpost; baseline = Cpost
- For studies with before/after measurements but no concurrent comparison, Ipost - Ipre; baseline = Ipre

where,

Ipost = last reported coverage in the intervention group after the intervention.

Ipre = reported coverage in the intervention group immediately before the intervention.

Cpost = last reported coverage in the comparison group after the intervention. And,

Cpre = reported coverage in the comparison group immediately before the intervention.

In the studies, vaccination coverages could have been measured as series-complete (i.e., proportion of persons up-to-date with each of several vaccinations) or as one or more individual vaccinations. When a study presented more than one vaccination result (but not a series-complete measure), we used an equally weighted average of percentage point changes. Studies without coverage outcomes, or for which percentage point changes were not calculable, were not included in descriptive statistics or in figures. However, these studies are described in the text and in Appendix B.

We then selected effect measures. When available, we used measures adjusted for potential confounders in multivariate analyses in preference to crude effect measures. In children, we used outcome measures among children closest to age 2 years. In studies that made comparisons between multiple groups, we compared each intervention group with the group that received no intervention or the least-intensive intervention. We included separate effect measures where possible for children, adolescents, and adults, but did not otherwise report different effect measures for different subpopulations.

The strength of the body of evidence was characterized as strong, sufficient, or insufficient on the basis of the numbers of available studies, strength of their design and execution, and size and consistency of reported effects (Table A-1). Sufficient and strong evidence could have been achieved in several ways that incorporate scientific rigor and feasibility and appropriateness of evaluation for the range of interventions used in population-based prevention and control efforts. Expert opinion was not used to support recommendations in this chapter.

Table A-1. Assessing the Strength of a Body of Evidence of Effectiveness of Population-Based Interventions in the Guide to Community Preventive Services

Evidence of Effectiveness* | Execution ^**^ | Design Suitability | Number of Studies | Consistency | Effect Size^¶^ | Expert Opinion^§^
| Good | Greatest | Two, Minimum | Yes | Sufficient | Not Used
| Good | Greatest or Moderate | Five, Minimum | Yes | Sufficient | Not Used
Strong | Good or Fair | Greatest | Five, Minimum | Yes | Sufficient | Not Used
| Met Design, Execution, Number, and Consistency Criteria for Sufficient But Not Strong Evidence | | | | Large | Not Used
| Good | Greatest | One | Not Applicable | Sufficient | Not Used
Sufficient | Good or Fair | Greatest or Moderate | Three,Minimum | Yes | Sufficient | Not Used
| Good or Fair | Greatest, Moderate, or Least | Five, Minimum | Yes | Sufficient | Not Used
Expert Opinion | Varies | Varies | Varies | Varies | Sufficient | Supported Findings
Insufficient*** | A Insufficient Designs or Execution | | B Too Few Studies | C Inconsistent | D Small | E Not Used

* *Categories were not mutually exclusive; a body of evidence meeting criteria for more than one of these was categorized in the highest possible level.

** Studies with limited execution were not used to assess effectiveness.

¶ Sufficient and large effect sizes were defined on a case-by-case basis and were based on opinion.

§ Expert opinion was not used in this chapter but could affect the classification of a body of evidence as demonstrated.

*** Reasons for a determination that evidence was insufficient is described as follows: A -Insufficient designs or executions; B - Too few studies; C - Inconsistent; D - Effect size too small; E - Expert opinion not used. These categories were not mutually exclusive, and one or more of these could have occurred when a body of evidence failed to meet the criteria for strong or sufficient evidence.

The primary factor in determining an intervention's recommendation was evidence of effectiveness. Generally, strength of evidence of effectiveness linked directly to strength of recommendation - Strong evidence of effectiveness led to strong recommendations. Inconsistent evidence based on definable characteristics of population, setting, or the intervention led to separate recommendations for various situations. For example, standing orders were recommended for adults but found to have insufficient evidence in children. Other interventions might have been recommended in health department clinics but not in managed care organizations, and more-intensive interventions might have been recommended over less-intensive ones. Insufficient or contradictory evidence, without evidence that the intervention was effective in one or more definable contexts, might have led to a determination that evidence was insufficient to assess effectiveness in any population. A determination that evidence is insufficient is important for identifying areas of uncertainty but should not be confused with evidence of ineffectiveness. Insufficient evidence leads to a detailed description of the current knowledge regarding the effectiveness of the intervention and a list of specific continuing research needs. In contrast, evidence of ineffectiveness leads to a recommendation that the intervention not be used. Evidence other than effectiveness was sometimes incorporated into the recommendations and was routinely summarized for users.

##### Applicability

To assist users in determining the likelihood that available information will or will not apply to their local situations, our chapter development team -

- defined target populations and settings for which the intervention might be considered;
- assessed whether available studies have evaluated the intervention in those populations and settings;
- assessed the extent to which populations or settings in those studies were likely to represent target populations and settings of interest; and
- judged whether the intervention worked better or worse in some populations and settings than in others.

On the basis of that information, the team made a judgment regarding how widely resulting recommendations should apply, and we identified areas for further research.

TABLE A-1. Assessing the Strength of a Body of Evidence of Effectiveness of Population-Based Interventions in the Guide to Community Preventive Services

##### Other Effects

Health interventions intended to influence one or more health outcomes sometimes could have resulted in other effects (i.e., positive and negative health or nonhealth "side effects"). The chapter development team also systematically searched for and evaluated the strength of evidence supporting these other effects, using the same process that was used for effectiveness. If other effects were demonstrated, they are discussed in the chapter. Documented harms that outweighed benefits could have led to negative recommendations. Interventions for which important distribution considerations existed (i.e., effective in some populations but harmful to one or more "side populations") could have led to more narrowly targeted or less positive recommendations than otherwise would have been made. Any available information regarding other effects that were positive or negative was documented; however, other nonhealth effects by themselves (i.e., without sufficient or strong evidence of effectiveness [i.e., improved health outcomes]) were not used to justify positive recommendations.

##### Economic Evaluations

Review of economic evaluation studies was performed for strongly recommended and recommended interventions only. To be included in the reviews, a study had to -

- use an analytical method (e.g., cost analysis, cost-effectiveness analysis, cost-benefit analysis, or cost-utility analysis);
- have a publication date of 1980-1998;
- address universally recommended adult, adolescent, or childhood vaccinations;
- be a primary study rather than, for example, a guideline or review;
- be performed in the Established Market Economies (EME) as described by the World Bank ( 1 );
- be written in English;
- meet the chapter development team's definition of one or more interventions;
- provide an economic evaluation of an intervention as described in the chapter rather than economic evaluation of a vaccine; and
- report sufficient information so that an adjusted estimate of cost, cost-effectiveness, cost-utility, or cost-benefit could be made.

A standardized abstraction form (Carande-Kulis, VG et al. 1999, to be published) was used for abstracting and adjusting data to meet the reference case suggested by the panel on cost-effectiveness in health and medicine ( 2 ). Using the abstraction form, costs were adjusted to 1997 U.S. dollars. The cost-effectiveness ratio was defined, for this chapter, as cost of the program per additional vaccination or cost per fully vaccinated child. Average cost was defined as cost of the program per person or vaccination. Where possible, cost of vaccinations were excluded to avoid overestimating costs of the intervention themselves. Ratios and averages < 10 were cited with two decimal points. Ratios and averages > 11 were rounded to the nearest integer. For interventions with four or more cost-effectiveness ratios, ratio distribution was described by the median and range. (For a complete listing of ratios and average costs, refer to Appendix C.)

##### Summarizing Barriers to Implementation of Interventions

Information regarding barriers to implementation of the interventions are described in the main text. Information on barriers did not affect recommendations.

##### Summarizing Research Gaps

Systematic reviews in the Guide identify existing information on which to base public health recommendations. An important additional benefit of these reviews is identification of areas where information is lacking or of poor quality. Note: Many major areas of vaccine-preventable disease research (e.g., epidemiology of vaccine-preventable diseases, clinical and laboratory features of vaccine-preventable diseases, and vaccine development and efficacy) and some areas of intervention research were not reviewed and are thus not represented in the sections on research gaps. To develop these sections, we used the following process:

- We identified remaining research questions for each intervention evaluated.
- In cases of interventions for which evidence was sufficient or strong enough to makae a recommendation, we summarized remaining questions regarding effectiveness, applicability, other effects, economic consequences, and barriers.
- In cases of interventions for which evidence was not sufficient enough to make a recommendation, we summarized remaining questions regarding effectiveness and other effects. We summarized applicability issues only if they affected the assessment of effectiveness. We decided that identifying research gaps in applicability, barriers, or economic evaluation before effectiveness was demonstrated would be premature.
- For each category of evidence, we identified issues that had emerged from the review, based on the informed judgement of the chapter development team. Several factors influenced that judgement. General
  - - We avoided addressing downstream issues if we could not address upstream issues. For example, if no study had answered whether the intervention was effective, we did not ask what might increase effectiveness. Similarly, if cost-effectiveness data were unavailable, we did not ask how efficiency might be improved.
  - - If no information or inadequate information existed to draw a conclusion regarding effectiveness, applicability, other effects, or economic evaluations, we listed these as evidence gaps.
  - - When a conclusion was drawn regarding evidence, we applied team judgement regarding whether issues remained.
  Effectiveness
  - - We did not necessarily identify studies that would simply change a body of evidence from sufficient to strong as evidence gaps.
  - - If effectiveness was demonstrated using some but not all outcomes, we did not necessarily list all other possible outcomes as evidence gaps.
  Applicability
  - - If available evidence was thought to generalize, we did not necessarily identify all subpopulations or settings where studies had not been done as evidence gaps.
- Following the reviews of individual interventions, we considered whether overriding methodologic issues existed.

#### Appendix A References

Murray AJL, Lopez AD, eds. Global burden of disease. Boston, MA: Harvard School of Public Health for The World Health Organization and the World Bank, 1996, 26-27.
Gold MR, Siegel JE, Russell LB, Weinstein MC. Cost-effectiveness in health and medicine. New York, NY: Oxford University Press 1996.

### Appendix B Evidence Figures and Tables Summarizing Effectiveness

Appendix B Nomenclature

CI | confidence interval
CDC | Centers for Disease Control and Prevention
DT | pediatric formulation of diphtheria and tetanus toxoids
DTP | diphtheria-tetanus toxoids and pertussis vaccine
GAO | U.S. General Accounting Office
Hib | Haemophilus influenzae type b conjugate vaccine
MMR | measles, mumps, and rubella vaccine
OPV | oral poliovirus vaccine
Td | adult formulation of diphtheria and tetanus toxoids
VA | Veterans' Administration
WIC | Special Supplemental Nutrition Program for Women, Infants, and Children, which is administered by the U.S. Department of Agriculture

Figure B-1a Client Reminder/Recall - Percentage Point Change in Vaccination Coverage Strongly Recommended

Figure B-1b Client Reminder/Recall - Percentage Point Change in Vaccination Coverage Strongly Recommended

Figure B-2 Multicomponent Interventions That Include Education - Percentage Point Change In Vaccination Coverage Strongly Recommended

Figure B-3 Vaccination Requirements For Child Care, School, And College Attendance - Percentage Point Change In Vaccination Coverage Recommended

Figure B-5 Clinic-Based Education Only - Percentage Point Change in Vaccination Coverage Insufficient Evidence

Figure B-6 Client Or Family Incentives - Percentage Point Change In Vaccination Coverage Insufficient Evidence

Figure B-7 Client-Held Medical Records - Percentage Point Change In Vaccination Coverage Insufficient Evidence

Figure B-8 Reducing Out-of-Pocket Costs - Percentage Point Change in Vaccination Coverage Strongly Recommended

Figure B-9 Expanding Access in Healthcare Settings - Percentage Point Change in Vaccination Coverage Strongly Recommended as Part of Multicomponent Intervention Insufficient Evidence When Used Alone

Figure B-10 Vaccination Programs In WIC Settings - Percentage Point Change In Vaccination Coverage Recommended

Figure B-11 Home Visits - Percentage Point Change In Vaccination Coverage Recommended

Figure B-14 Provider Reminder/Recall-Percentage Point Change In Vaccination Coverage Strongly Recommended

Figure B-15 Assessment and Feedback for Vaccination Providers - Percentage Point Change In Vaccination Coverage Strongly Recommended

Figure B-16 Standing Orders - Percentage Point Change in Vaccination Coverage Among Adults Strongly Recommended for Adults Insufficient Evidence for Children

Figure B-17 Provider Education Only - Percentage Point Change in Vaccination Coverage Insufficient Evidence

#### Table B-1 Client Reminder/Recall Strongly Recommended

Table B-1 Client Reminder/Recall Strongly Recommended

Table B-1 Client Reminder/Recall Strongly Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Client Reminders/Recall Only
Alemi Ref. 1 1993-94 | Nonrandomized trial, greatest suitability, fair | Cleveland, Ohio; clinics/offices; clients - aged <6 months; urban; 81%-88% black; low socioeconomic status | 1 Computer-generated client telephone reminders and recalls versus; 2 Comparison group of usual care (Total study population, 213 participants) | Up-to-date with DTP/OPV/MMR/Hib vaccinations, 1 versus 2 = 25% change (p < 0.005)
Alto Ref. 2 1991 | Randomized trial, greatest suitability, fair | Colorado; family practice residency clinic; clients - aged >2 months and <7 years; 17% Hispanic; urban; 51% male; low socioeconomic status | 1 Mailed and telephone client reminders versus; 2 Comparison group of usual care (Total study population, 464 participants before randomization) | Up-to-date with DTP/OPV/MMR/Hib vaccinations, 1 versus 2 = 8% change (p < 0.011)
Barnas Ref. 3 Time not reported | Randomized trial, greatest suitability, fair | Milwaukee, Wisconsin; primary-care clinic; clients - aged >65 years, mean 74 years; urban/suburban; 51% black; 70% female | 1 Mailed client reminder for influenza plus reminders to attend clinic versus; 2 Comparison group receiving reminder to attend clinic (Total study population, 804 participants) | Influenza, 1 versus 2 = -7% change (p < 0.04)
Brimberry Ref. 4 1984-85 | Randomized trial, greatest suitability, fair | Little Rock, Arkansas; family practice residency clinic; clients - adults; urban/suburban/rural; otherwise, not well-described | 1 Mailed client reminder versus; 2 Telephone client reminder versus; 3 Comparison group of usual care (Total study population, 787 participants) | Influenza, 1 versus 3 = 5.9% change (p < 0.02); 2 versus 3 = 5.5% change (p < 0.02); no difference between mail and telephone reminders
Buchner Ref. 5 1984 | Randomized trial, greatest suitability, fair | Seattle, Washington; private practice offices; clients - aged >65 years, mean 76 years; suburban/rural; 66% female; low/middle socioeconomic status | 1 Mailed client remainder versus; 2 Comparison group of usual care (Total study population, 540 analyzed) | Influenza, 1 versus 2 = 1% change (nonsignificant)
Campbell Ref. 6 Time not reported | Randomized trial, greatest suitability, good | Rochester, New York; pediatric community clinic at Strong Memorial Hospital; clients - aged birth-13 months; urban; 49%-55% female; 60%-67% black; low socioeconomic status | 1 Mailed letter reminders for well child care (87 participants) versus; 2 Mailed postcard reminders (96) versus; 3 Comparison group of usual care (105) | DTP by age 7 months, 1 versus 3 = 6% change; 2 versus 3 = 2% change (p = 0.72 for differences between the three groups)
Carter Ref. 7 Time not reported | Randomized trial, greatest suitability, fair | Seattle, Washington; ambulatory clinic at VA hospital; clients - adults; urban; not vaccinated in the year before the intervention | 1 Standard client reminder letter plus brochure (66 participants) versus; 2 Augmented client reminder letter plus brochure (55) versus; 3 Augmented client reminder letter (57); 4 Comparison group of standard client reminder letter (57) | Influenza, 1 versus 4 = 13% change (p < 0.05); 2 versus 4 = 23% (p <.05), 3 versus 4 = 7% (nonsignificant); influenza, combined 1 and 2 versus 3 and 4 = 13% (p < 0.025)
CDC Ref. 8 1994 | Group randomized trial, greatest suitability, fair | Montana and Wyoming; communitywide; clients - aged >65 years; mostly rural | 1 Mailed "personal letter" reminders (87 participants) versus; 2 Mailed brochure reminders (96) versus; 3 Comparison group of usual care (105) All groups received public service announcements and provider reminders | Influenza, 1 and 2 combined versus 3 = 6.1% (CI = 5.5%-6.7%)
Grabenstein Ref. 9 1993 | Randomized trial, greatest suitability, good | Durham County, North Carolina; community pharmacies; clients - mean age 67 years; 62% female, 79% white, socioeconomic status mid/high | 1 Mailed letter on pharmacy stationary relating risk and availability of vaccination (242 participants) versus; 2 Mailed letter regarding "poison proofing" home (240) Both groups received reminder letter 2-3 weeks later | Influenza, 1 versus 2 = 10% (CI = 1%-19%)
Larson Ref. 10 1978-79 | Randomized trial, greatest suitability, fair | Seattle, Washington; University of Washington Family Medicine Center; clients - mean age 67 years; 68% female | 1 Neutral card stating availability of vaccinations versus; 2 Health belief model card versus; 3 Personal card signed by physician versus; 4 Comparison group of usual care (Total study population, 283 participants) | Influenza, 1 versus 4 = 5% change; 2 versus 4 = 31% (p < 0.001); 3 versus 4 = 21% (p < 0.025); 2 versus 1 = 26% (p < 0.01); 3 versus 1 = 16% (p < 0.1)
Lieu Ref. 11 1994-95 | Randomized trial, greatest suitability, fair | Northern California; managed care organization; clients - aged 20-24 months; middle/upper socioeconomic status | 1 Computer-generated personalized letter client recalls (172 participants) versus; 2 Comparison group of usual care (149) | MMR by age 24 months, 1 versus 2 = 1.7% change (p < 0.001)
McDowell Ref. 12 Rosser Ref. 13 1983-85 | Group randomized trial (by family), greatest suitability, fair | Ottawa, Canada; University of Ottawa Family Medicine Center at Civic Hospital; providers, staff and resident physicians, nurses; clients - aged >65 years for influenza and > 20 years for tetanus | 1 Computer-generated provider reminder (218 participants) versus; 2 Client reminder by telephone (226) versus; 3 Client reminder by letter (231) versus; 4 Comparison group of randomized controls (230) | Influenza, 1 versus 4 = 13% change (p < 0.005); 2 versus 4 = 26% (p < 0.005); 3 versus 4 = 26% (p < 0.005) ; Td, 1 versus 4 = 20% (CI = 17%-22%); 2 versus 4 = 21% (CI = 18%-24%); 3 versus 4 = 27% (CI = 25%-31%)
Moran Ref. 14 Time not reported | Randomized trial, greatest suitability, fair | North Carolina ambulatory general internal medicine and gerontology clinic; clients - mean age 76 years; 65% female | 1 Client reminded with brochure (450 participants) versus; 2 Comparison group of usual care (450) | Influenza, 1 versus 2 = 1% change (p > 0.5)
Mullooly Ref. 15 1984-85 | Nonrandomized trial, greatest suitability, fair | Portland, Oregon; managed care organization; clients - aged >65 years; 47%-52% female | 1 "Personalized" client reminder letter (1,105 participants) versus; 2 Comparison group of usual care (1,112) | Influenza, 1 versus 2 = 9% change (CI = 5%-13%); adjustment for the excess of males in the intervention group moderated the change to 8%
Siebers Ref. 16 1982-83 | Randomized trial, greatest suitability, fair | Madison, Wisconsin; general internal medicine clinic, University of Wisconsin hospital; clients - aged >65 years; otherwise, target population not described | 1 Client reminder letter (173 participants) versus; 2 Comparison group of usual care (92) | Pneumococcal, 1 versus 2 = 13% change (significant)
Spaulding Ref. 17 1983-84 | Randomized trial, greatest suitability, fair | Fort Lewis, Washington; military-affiliated family practice department; clients - aged birth->64 years; 43%-50% female | 1 Client reminder postcard (519 participants) versus; 2 Comparison group of usual care (549) All clients received enhanced clinic access and free vaccination | Influenza, 1 versus 2 = 27% change (p < 0.001) for those aged >65 years; influenza, 1 versus 2 = 16% (p < 0.001) for all ages
Stehr-Green Ref. 18 Time not reported | Randomized trial, greatest suitability, fair | Atlanta, Georgia; public health clinics; clients - aged <2 years, average 8.7-9.2 months | 1 Computer-generated telephone reminder (101 participants) versus; 2 Comparison group of usual care (96) | DTP, 1 versus 2 = 3% change (nonsignificant)
Tollestrup Ref. 19 1987 | Nonrandomized trial; greatest suitability, fair | Everett and Snohomish Counties, Washington; county health department clinic; clients - aged <5 years | 1 Client recall letter if 1 month overdue (182 participants) versus; 2 Comparison group of usual care (211) | DTP vaccination within 5 months, 1 versus 2 = 18% change (p < 0.01)
Tucker Ref. 20 1980-83 | Time-series, moderate suitability, fair | Syracuse, New York; family practice residency model office, faculty private office; clients - aged >65 years; otherwise, not well-described | 1 Mailed client reminder letter from residency director (856 clients of model office) versus; 2 Same but stronger wording and signed by client's physician (1251 clients of model office, 249 clients of private office) versus; 3 Prior usual care (75 clients of model office, 75 clients of private office) | Model office - Influenza, 1 versus 3 = 7% change (nonsignificant); 2 versus 3 = 7% (nonsignificant); private office - influenza, 2 versus 3 = 7% (nonsignificant)
Effects of Client Reminder/Recall in Combination with Other Interventions
Barton Ref. 21 1983-87 | Time-series, moderate suitability, fair | Boston, Massachusetts; clinic/provider's offices; clients - aged >65 years; urban | 1 Client reminders plus client education plus provider reminders versus; 2 Same plus feedback to individual physicians versus; 3 Previous usual care (Total study population, 647 participants) | Influenza, 1 versus 3 = 18% change; 2 versus 3 = 36% (statistical significance not reported)
Becker Ref. 22 1986-87 | Randomized trial, greatest suitability, fair | Charlottesville, Virginia; University of Virginia medicine clinic; providers: residents; clients - aged 40-60 years, mean 51-52; 64%-72% female; 50%-60% black; low socioeconomic status | 1 Physician and client reminders (168 participants) versus; 2 Physician reminders (203) versus; 3 Comparison group (192) | Influenza, pneumococcal, and Td, 2 versus 3 = 9%, 2%, and 6% change; 1 versus 3 = 16%, 1%, 8% (analysis of variance for groups 1, 2, and 3 only significant for Td)
Browngoehl Ref. 23 Kennedy Ref. 24 1992-93 | Retrospective cohort study; moderate suitability; fair | Philadelphia, Pennsylvania; Medicaid managed care group; clients - aged 30-35 months (control group) and 18-24 months (study group); low socioeconomic status | 1 Tracking and reminders plus provider education and incentives plus parent education and incentives plus transportation assistance plus home visits (1,254 participants) versus; 2 Control group of older children (1,257) | 4 DTP/3 OPV/1 MMR at age 35 months, 1 versus 2 = 7% change (p < 0.05); 4 DTP/3 OPV/1 MMR/1 Hib at age 35 months, 1 versus 2 = 2% change (nonsignificant) Higher coverage in children who received home visits (significance not given)
Buffington Ref. 25 1989 | Randomized trial, greatest suitability, fair | Rochester, New York; private physician offices; clients - aged >65 years; urban/suburban; otherwise, target population not well-described | 1 Provider feedback versus; 2 Provider feedback plus mailed client remainders versus; 3 Comparison group of usual care (Total study population, 10,525 participants) | Influenza, 1 versus 3 = 16% change (p < 0.001); 2 versus 3 = 17% (p < 0.001)
Frame Ref. 26 1991-92 | Group randomized trial, greatest suitability, fair | Dansville, New York; family practice offices; providers - family physicians and physician's assistants; clients - aged >21 years; rural; low/middle socioeconomic status | 1 Computer-based telephone client reminders plus provider reminders on chart (829 participants) versus; 2 Comparison group of client reminders triggered by physician request (836) | Td, 1 versus 2 = 21% change (CI = 16%-26%); change for all preventive care was 11%
Hutchison Ref. 27 Frank Ref. 28 1981-87 | Time-series study, moderate suitability; fair | Hamilton, Ontario; community clinic; clients - aged >65 years; urban; 66% female | 1 Mailed client reminder letter (273 participants) and associated drop-in clinics versus; 2 Prior usual care | Influenza, 1 versus 2 after 6 years = 35% change (statistical testing not reported)
Karuza Ref. 29 1990-92 Calkins Ref. 30 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart and/or client reminders and/or waiting room posters and/or provider education and/or standing orders and/or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Lukasik Ref. 31 1985 | Nonrandomized trial, greatest suitability, fair | London, Ontario; Victoria Family Medicine Center; clients - aged >65 years; otherwise, not well-described | 1 Provider reminders on chart plus client education plus waiting room poster plus client reminders plus increased access (120 participants) versus; 2 Provider reminders on chart plus client education plus poster (123) versus; 3 Previous usual care | Influenza, 1 versus 2 = 22% change (p = 0.002); 1 versus 3 = 44%; 2 versus 3 = 22%
Margolis Ref. 32 1989-90 | Nonrandomized trial, greatest suitability, fair | Urban/suburban Minneapolis-St. Paul, Minnesota; staff model health maintenance organization; clients - aged >65 years | 1 Standing orders, client reminder/recall, provider education, expanded access versus; 2 Usual care Two clinics in each group; outcomes assessed in 150 randomly chosen clients/clinic | Influenza, intervention clinic 1 versus comparison clinic 1 = -8% change; intervention clinic 2 versus comparison clinic 2 = 20%; post- versus prechange in intervention clinic 2 (significant, p = 0.01); changes in other clinics nonsignificant
Moran Ref. 33 1990 | Randomized trial, greatest suitability, fair | Location not reported; community health center; clients - adults; urban; 61% female | 1 Single client reminder letter (135 participants) versus; 2 Two client reminder letters (138) versus; 3 Comparison group of usual care (136) Vaccination available free and without appointment | Influenza, 1 versus 3 = 2% change (nonsignificant); 2 versus 3 = -8% (nonsignificant)
Nichol Ref. 34 1987 Nichol Ref. 35 1987-92 | Other designs with concurrent comparison groups, greatest suitability, time-series study, moderate suitability, both fair | Minneapolis, Minnesota, versus other midwestern cities; VA outpatient services; clients - veterans | 1 Standing orders, walk-in "flu-shot" clinics, vaccination stations in busy clinic areas, mailing to all outpatients (378 participants) versus; 2 Usual care at 3 other midwestern academic hospitals (997) | Influenza, 1 versus 2 = 26% change (p < 0.00001); time-series data found that coverage rates continued to increase for 5 years; additional 15% among all clients (p < 0.0001)
O'Sullivan Ref. 36 Time not reported | Randomized trial, greatest suitability, fair | Eastern United States; large urban teaching hospital; clients - maternal aged <17; 100% black; low socioeconomic status | 1 Education and rigorous follow-up relating to family planning, parenting behaviors, return to school, health education, recall phone calls/letters, client-held vaccination records, lower costs versus; 2 Usual care | Children aged 18 months, 1 versus 2 = 15% change in up-to-date vaccination coverage (p < 0.02); mothers, clinic attendance and repeat pregnancy rates better in intervention group; return to school and emergency room use did not differ
Oeffinger Ref. 37 Time not reported | Nonrandomized trial, greatest suitability, fair | McLennan County, Texas; family practice residency program in hospital and clinic; clients - aged <1 year with 35%-39% adolescent mothers; 28%-36% Hispanic; 33%-47% black | 1 Client education at clinic plus client reminder letter (nonspecific) 2 months after birth versus; 2 Comparison group of usual care | Up-to-date with 3 DTP vaccination/2 OPV by 12 months, 1 versus 2 = -4% (p = 0.41)
Ohmit Ref. 38 1989-92 | Time-series study, moderate suitability, fair | Seven counties in southwest Michigan; clients - aged 65 years; otherwise, not described | 1 Communitywide education of physicians and clients plus free vaccination plus provider education plus client education plus mailed postcard client reminders plus outreach in senior centers (evaluated in 1,315 and 1,663 participants in 1990-91 and 1991-92, respectively) versus; 2 Prior usual care (client numbers not given) | Influenza, 1 versus 2 = 16% change (statistical significance not reported)
Paunio Ref. 39 1982-86 | Time-series study, moderate suitability, fair | Finland; communitywide; target population - aged birth-11 years | 1 Registry plus mass-media reporting of local data regarding vaccination coverage plus provider reminders plus parent reminders versus; 2 Usual care before registry | MMR, 1 versus 2 = 8% change (no significance testing) Fitted weekly time-series models of number of MMR delivered 1 versus 2, no effect on number of vaccinations administered to children aged 14-18 months; mass-media might have increased vaccinations administered to children aged 6 years; all three interventions increased numbers of children aged 6 years who received first MMR
Pierce Ref. 40 1989 (pre) 1993 (post) | Nonrandomized trial, greatest suitability, fair | Albuquerque, New Mexico; public health clinics; aged <12 months; 29%-70% Hispanic; most of remainder, white; 34% below poverty level | 1 Implementation of "Standards for Pediatric Vaccination Practices;" including evening and Saturday clinic hours plus client and provider education plus client reminders plus community involvement and outreach (846 participants pre, 309 post) versus; 2 Usual care (753 pre, 138 post) | Dropout, late start, and missed opportunities declined at intervention site relative to comparison; 3 DTP/2 OPV, 1 versus 2 = 17% increase at 7 months and 24% at 12 months (significance not tested because whole population included)
Soljak Ref. 41 1985 | Before/after study for provider reminders; least-suitable, fair; nonrandomized trial for client reminders, greatest suitability, fair | Northland, New Zealand; clinics, offices; clients - children; otherwise, not well-described | 1 Provider reminders by mail versus; 2 Provider reminders by mail plus client reminders versus; 3 Prior usual care (Size of target population not found) | Up-to-date with "all appropriate antigens" 1 versus 2 = "no significant difference"; 1 and 2 combined versus 3 = 5% at 5 months (risk ratio significant)
Waterman Ref. 42 1992-94 | Nonrandomized trial, greatest suitability, fair | San Diego County, California; clients - children aged 2-4 years; 87% Hispanic; low socioeconomic status | 1 Free walk-in vaccination clinics plus client reminders plus provider education plus multiple education and health promotion strategies plus assessment referral and education of WIC clients versus; 2 Comparison community of usual care | DTP/OPV/MMR (4:3:1 doses, respectively), 1 versus 2 = 12% (statistical significance not found)
Effects of Client Reminder/Recall Only and in Combination with Other Interventions
Moran Ref. 43 1991 | Randomized trial, greatest suitability, fair | Boston, Massachusetts; community health center clinics; clients - adults, mean age 66 years; urban; 33%-35% male; low socioeconomic status | 1 Mailed client reminders versus; 2 Lottery-type client incentive versus; 3 Both versus; 4 Comparison group of usual care (Total study population, 797 participants) All groups received walk-in vaccinations, free vaccinations, and health fair | Influenza, 1 versus 4 = 16% change; 2 versus 4 = 9%; 3 versus 4 = 6%; multivariate analysis odds ratios, 1 = 2.29% (CI = 1.45%-3.61%); 2 = 1.68% (CI = 1.05%-2.68%), 3 = 1.41% (CI = 0.88%-2.27%)
Nexøe Ref. 44 1995 | Randomized trial, greatest suitability, fair | Denmark; general practices; clients - adults >65 years; 60% female | 1 Mailed client reminders (195 participants) versus; 2 Mailed client reminder plus free vaccination (195) versus; 3 Comparison group of usual care (195) | Influenza, 1 versus 3 = 24% change; 2 versus 3 = 47% (no statistical tests for these comparisons)
Ornstein Ref. 45 1988-89 | Group randomized trial (by practice group), greatest suitability, fair | South Carolina; family medicine center at University of South Carolina; providers - faculty, residents, and fellows in family medicine; clients aged >18 years, mean age 40 years; urban; 61% female; 61% black; low socioeconomic status | 1 Computerized physician reminders on chart (1,988 participants) versus; 2 Client reminders (1,925) versus; 3 Physician and client reminders (1,908) versus; 4 Comparison group of usual care (1,576) | Td, 1 versus 4 = 6.7% change; 2 versus 4 = 5.7%; 3 versus 4 = 8.2%; significant improvements in 3 of 4 other preventive services
Satterthwaite Ref. 46 Time not reported | Randomized trial, greatest suitability, fair | Aukland, New Zealand; general practices; clients - aged >65 years; otherwise, target population not described | 1 "Personal" client reminder letter (931 participants) versus; 2 Same plus free vaccination offered in letter (930) versus; 3 Comparison group of usual care (930) | Influenza, 1 versus 3 = 10% change (p < 0.001); 2 versus 3 = 28% (p < 0.001)
Yokley Ref. 47 Time not reported | Group randomized trial by family, greatest suitability, fair | Akron, Ohio; public health clinic; clients aged <5 years, mean 37 months; 50% female; 64% white | 1 Mailed general client reminder (195 participants) versus; 2 Mailed specific client reminder (190) versus; 3 Mailed specific client reminder plus special off hours clinics (185) versus; 4 Mailed specific client reminder plus parent incentive lottery (183) versus; 5 Comparison group of usual care (191) | Vaccinated with at least 1 antigen after 3 months, 1 versus 5 = 3% change (not significant); 2 versus 5 = 13% (not significant); 3 versus 5 = 16% (significant); 4 versus 5 = 18% (significant)

##### References

Alemi F, Alemagno SA, Goldhagen J, et al. Computer reminders improve on-time immunization rates. Med Care. 1996;34:OS45-51. [pmid: 8843936].
Alto WA, Fury D, Condo A, Doran M, Aduddell M. Improving the immunization coverage of children less than 7 years old in a family practice residency. J Am Board Fam Pract. 1994;7:472-7. [pmid: 7847110].
Barnas GP, McKinney WP. Postcard reminders and influenza vaccination. J Am Geriatr Soc. 1989;37. [pmid: 2910979].
Brimberry R. Vaccination of high-risk patients for influenza: a comparison of telephone and mail reminder methods. J Fam Pract. 1988;26:397-400. [pmid: 3282026].
Buchner DM, Larson EB, White RF. Influenza vaccination in community elderly: a controlled trial of postcard reminders. J Am Geriatr Soc. 1987;35:755-60. [pmid: 3301990].
Campbell JR, Szilagyi PG, Rodewald LE, Doane C, Roughmann KJ. Patient-specific reminder letters and pediatric well-child-care show rates. Clin Pediatr. 1994;33(5):268-72.
Carter WB, Beach LR, Inui TS. Flu shot study: using multiattribute theory to design a vaccination intervention. Organizational Behavior and Human Decision Processes. 1986;38:378-91. [pmid: 10279492].
CDC. Increasing influenza vaccination rates for Medicare beneficiaries--Montana and Wyoming, 1994. MMWR. 1995;44:744-46. [pmid: 7565555].
Grabenstein JD, Hartzema AG, Guess HA, Johnston WP. Community pharmacists as immunization advocates: a pharmacoepidemiologic experiment. International Journal of Pharmacy Practice. 1993;2:5-10.
Larson EB, Bergman J, Heidrich F, Alvin BL, Schneeweiss R. Do postcard reminders improve influenza compliance? A prospective trial of different postcard "cues.". Med Care. 1982;20:639-48. [pmid: 7109747].
Lieu TA, Black SB, Ray P, et al. Computer-generated recall letters for underimmunized children: how cost-effective?. Pediatr Infect Dis J. 1997;16:28-33. [pmid: 9002097].
McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135:991-7. [pmid: 3093045].
Rosser WW, Hutchison BG, McDowell I, Newell C. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146:911-17. [pmid: 1544078].
Moran WP, Wofford JL, Velez R. Assessment of influenza immunization of community elderly: illustrating the need for community level health information. Carolina Health Services Review. 1995;3:21-9.
Mullooly JP. Increasing influenza vaccination among high-risk elderly: a randomized controlled trial of a mail cue in an HMO setting. Am J Public Health. 1987;77:626-7. [pmid: 3565663].
Siebers MJ, Hunt VB. Increasing the pneumococcal vaccination rate of elderly patients in a general internal medicine clinic. J Am Geriatr Soc. 1985;33:175-8. [pmid: 3973336].
Spaulding SA, Kugler JP. Influenza immunization: the impact of notifying patients of high-risk status. J Fam Pract. 1991;33:495-8. [pmid: 1940817].
Stehr-Green PA, Dini EF, Lindegren ML, Patriarca PA. Evaluation of telephoned computer-generated reminders to improve immunization coverage at inner-city clinics. Public Health Rep. 1993;108:426-30. [pmid: 8341774].
Tollestrup K, Hubbard BB. Evaluation of a follow-up system in a county health department's immunization clinic. Am J Prev Med. 1991;7:24-8. [pmid: 1907834].
Tucker JB, DeSimone JP. Patient response to mail cues recommending influenza vaccine. Fam Med. 1987;19:209-12. [pmid: 3596114].
Barton MB, Schoenbaum SC. Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health. 1990;80:534-6. [pmid: 2327527].
Becker DM, Gomez EB, Kaiser DL, Yoshihasi A, Hodge RH. Improving prevention care at a medical clinic: how can the patient help?. Am J Prev Med. 1989;5:353-9. [pmid: 2597431].
Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
Buffington J, Bell KM, LaForce FM. Target-based model for increasing influenza immunizations in private practice. J Gen Intern Med. 1991;6:204-9. [pmid: 2066823].
Frame PS, Zimmer JG, Werth PL, Jackson Hall W, Eberly SW. Computer-based vs manual health maintenance tracking: a controlled trial. Arch Fam Med. 1994;3:581-8. [pmid: 7921293].
Hutchison BG, Shannon HS. Effect of repeated annual reminder letters on influenza immunization among elderly patients. J Fam Pract. 1991;33:187-9. [pmid: 1890400].
Frank JW, Henderson M, McMurray L. Influenza vaccination in the elderly: 1. determinants of acceptance. CMAJ. 1985;132:371-5. [pmid: 3971253].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Lukasik MH, Pratt G. Telephone: an overlooked technology for prevention in family medicine. Can Fam Physician. 1987;33:1997-2001. [pmid: 21263970].
Margolis KL, Nichol KL, Wuorenma J, Von Sternberg TL. Exporting a successful influenza vaccination program from a teaching hospital to a community outpatient setting. J Am Geriatr Soc. 1992;40:1021-3. [pmid: 1401675].
Moran WP, Nelson K, Wofford JL, Velez R. Computer-generated mailed reminders for influenza immunization: a clinicaltrial. J Gen Intern Med. 1992;7:535-7. [pmid: 1403212].
Nichol KL, Korn JE, Margolis KL, Poland GA, Petzel RA, Lofgren RP. Achieving the national health objective for influenza immunization: success of an institution-wide vaccination program. Am J Med. 1990;89:156-60. [pmid: 2382664].
Nichol KL. Long-term success with the national health objective for influenza vaccination: an institution-wide model. J Gen Intern Med. 1992;7:595-600. [pmid: 1453242].
O'Sullivan AL, Jacobsen BS. Randomized trial of a health care program for first-time adolescent mothers and their infants. Nurs Res. 1992;41:210-5. [pmid: 1408861].
Oeffinger KC, Roaten SP, Hitchcock MA, Oeffinger PK. Effect of patient education on pediatric immunization rates. J Fam Pract. 1992;35:288-93. [pmid: 1517726].
Ohmit SE, Furumoto-Dawson A, Monto AS, Fasano N. Influenza vaccine use among an elderly population in a community intervention. Am J Prev Med. 1995;11:271-6. [pmid: 7495605].
Paunio M, Virtanen M, Peltola H, et al. Increase of vaccination coverage by mass media and individual approach: intensified measles, mumps, and rubella prevention program in Finland. Am J Epidemiol. 1991;133:1152-60. [pmid: 2035518].
Pierce C, Goldstein M, Suozzi K, Gallaher M, Dietz V, Stevenson J. Impact of the standards for pediatric immunization practices on vaccination coverage levels. JAMA. 1996;276:626-30. [pmid: 8773635].
Soljak MA, Handford S. Early results from the Northland immunisation register. N Z Med J. 1987;100:244-6. [pmid: 3454893].
Waterman SH, Hill LL, Robyn B, et al. Model immunization demonstration for preschoolers in an inner-city barrio, San Diego, California, 1992-94. Am J Prev Med. 1996;12(Suppl 1):8-13. [pmid: 8874698].
Moran WP, Nelson K, Wofford JL, Velez R, Case LD. Increasing influenza immunization among high-risk patients: education or financial incentive. Am J Med. 1996;101:612-20. [pmid: 9003108].
Nexøe J, Kragstrup J, Rønne T. Impact of postal invitations and user fee on influenza vaccination rates among the elderly: a randomized controlled trial in general practice. Scand J Prim Health Care. 1997;15:109-12. [pmid: 9232713].
Ornstein SM, Garr DR, Jenkins RG, Rust PF, Arnon A. Computer-generated physician and patient reminders: tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32:82-90. [pmid: 1985140].
Satterthwaite P. Randomized intervention study to examine the effect on immunization coverage of making influenza vaccine available at no cost. N Z Med J. 1997;110:58-60. [pmid: 9076288].
Yokley JM, Glenwick DS. Increasing the immunization of preschool children: an evaluation of applied community interventions. J Appl Behav Anal. 1984;17:313-25. [pmid: 6439714].

#### Table B-2 Multicomponent Interventions That Include Education Strongly Recommended

Table B-2 Multicomponent Interventions That Include Education Strongly Recommended

Table B-2 Multicomponent Interventions That Include Education Strongly Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Multicomponent Communitywide Interventions That Include Education
Etkind Ref. 1 1988-92 | Nonrandomized trial, greatest suitability, fair | Essex and Worcester Counties, Massachusetts; communitywide; Essex county target population - 90% urban; aged >65 years; predominantly white; socioeconomic status not reported | 1 Multiple approaches to promoting influenza vaccination to target population plus provider education plus administration fee to providers (91,621 Medicare Part B enrollees) versus; 2 Baseline in intervention county (number not provided) versus; 3 Usual practice in comparison county (95,234 Medicare Part B enrollees) | 1 versus 2 = 29% change (statistical significance not provided); 1 versus 3, doses distributed in Essex County increased from ~25,000/year before to ~57,400/year after versus no change in comparison county
Holtman Ref. 2 1989 and 1990 | Cross-sectional study, least-suitable; fair | United States nationwide; communitywide; aged 2 years, otherwise, target population not well-described | 1 Presence of education and tracking systems or free vaccinations as reported by states to GAO or CDC versus; 2 Lack of those interventions as reported by states | By ordinary least squares regression, states with universal vaccine provision programs have vaccination coverages among children aged 2 years that are higher than states with neither a universal vaccination provision plan or a vaccination replacement plan, all else being equal; 10% difference, p = 0.11, CDC data; 9% difference, p = 0.035, GAO data Presence of an education and tracking system had variable relationships to vaccination coverage; 0% difference, p = 0.99, CDC data; 9% difference, p = 0.011, GAO data
Macdonald Ref. 3 1979-81 | Before/after study, least-suitable, fair | South Australia; communitywide; target population not described | 1 Provider education plus mass-media campaign plus dedicated vaccination clinics versus; 2 Usual care before campaign (Size of target population not provided) | Survey of a convenience sample found 19% could recall campaign without prompting (2/3 could recall with prompting); attendance for MMR in 1981 versus 1979-80 was 14% greater before the campaign and 90% greater after
Ohmit Ref. 4 1989-91 | Time-series study, moderate suitability, fair | Southwest Michigan; communitywide; clinics/offices target population - >65 years; otherwise, incompletely described | 1 Communitywide education of physicians and clients plus free vaccination plus mailed postcard client reminders plus outreach in senior centers (evaluation in 1,315 participants in 1990-91 and 1,663 in 1991-92) versus; 2 Prior usual care (client numbers not given) (Number in whom baseline was assessed not given) | Influenza, 1 versus 2 = 16% change (statistical significance not found)
Paunio Ref. 5 1982-86 | Time-series study, moderate suitability, fair | Finland; communitywide; target population - aged birth-11 years | 1 Registry plus mass-media reporting of local data regarding vaccination coverage plus provider reminders plus parent reminders versus; 2 Usual care before registry | MMR, 1 versus 2 = 8% change (no significance testing) Fitted weekly time-series models of number of MMR delivered 1 versus 2, no effect on number of vaccinations administered to children aged 14-18 months; mass-media might have increased vaccinations administered to children aged 6 years; all three interventions increased numbers of children aged 6 years who received first MMR
Waterman Ref. 6 1992-94 | Nonrandomized trial, greatest suitability, fair | San Diego County, California; target population - children aged 2-4 years; 87% Hispanic; low socioeconomic status | 1 Free walk-in vaccination clinics plus client reminders plus provider education plus multiple education and health promotion strategies plus assessment referral and education of WIC clients versus; 2 Comparison community of usual care | DTP/OPV/MMR (4:3:1 doses, respectively), 1 versus 2 = 12% (statistical significance not found)
Effects of Multicomponent Interventions That Include Education in Clinical Settings
Browngoehl Ref. 7 Kennedy Ref. 8 1992-93 | Retrospective cohort study; moderate suitability; fair | Philadelphia, Pennsylvania; Medicaid managed care group; clients - children aged 30-35 months(control group) and 18-24 months (study group), low socioeconomic status | 1 Tracking and reminders plus provider education and incentives plus parent education and incentives plus transportation assistance plus home visits (1,254 participants) versus; 2 Control group of older children (1,257) | 4 DTP/3 OPV/1 MMR at age 35 months, 1 versus 2 = 7% change (p < 0.05); 4 DTP/3 OPV/1 MMR/1 Hib at age 35 months, 1 versus 2 = 2% change (nonsignificant) Higher coverage in children who received home visits (significance not given)
Dickey Ref. 9 1988-89 | Nonrandomized trial, greatest suitability, fair | San Francisco, California; family practice residency clinic; clients - mean age 55 years; urban; 49%-55% Spanish speaking | 1 "Health diary" regarding vaccinations and other preventive services given to providers and clients plus posters in waiting room (200 participants) plus client education delivered by nursing staff versus; 2 "Health diary" given to providers | Influenza, 1 versus 2 = 15% change (significant) at 6 months and -7% at 18 months; Td, 1 versus 2 = 4% at 6 months and 7% (significant) at 18 months; pneumococcal, 1 versus 2 = -1% at 6 months and 16% at 18 months; performance in 8 preventive services, 1 versus 2 = 11% change at 6 months (p < 0.001) and 9% at 18 months (p = 0.006)
Elangovan Ref. 10 1995 | Before/after study, least-suitable, fair | Wichita, Kansas; university ambulatory care clinic; clients - aged >65 years; 70% white | 1 Client educational materials regarding pneumococcal vaccinations provided in waiting room and discussed if necessary; if client consented, chart was flagged for provider (535 participants) versus; 2 Usual care before campaign | Pneumococcal vaccination, 1 versus 2 = 25% change (p < 0.001)
Elster Ref. 11 1983-84 | Nonrandomized trial, greatest suitability, fair | Utah; University of Utah School of Medicine; mothers aged 19 years; 14%-22% of study population Hispanic; mixed socioeconomic status | 1 Adolescent mother and child program included nutrition and psychosocial assessments, medical care for mother-infant pairs, counseling, nutrition, and medical services, staff available nights and weekends versus; 2 Usual care for clients recruited from the other local WIC program | Up-to-date vaccinations among infants, 1 versus 2 = 13% change at 12 months and 17% change at 26 months (p < 0.05 both comparisons); multiple nonvaccination outcomes also improved
Herman Ref. 12 1989-90 | Randomized trial, greatest suitability, good | Cleveland, Ohio; academic clinical organization; clients - >65 years, 67% female, predominantly white | 1 Standing orders/client education/provider education (prevention team) (387 participants) versus; 2 Client/provider education (389) versus; 3 Provider education (426) | Influenza, 1 versus 3 = 13% change; pneumococcal, 19% (significant); 2 versus 3 = 3% influenza and 2% pneumococcal (nonsignificant)
Karuza Ref. 13 1990-92 Calkins Ref. 14 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart or client reminders or waiting room posters or provider education or standing orders or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Lukasik Ref. 15 1985 | Nonrandomized trial, greatest suitability, fair | London, Ontario; Victoria Family Medicine Center; clients - aged >65 years; otherwise, not well-described | 1 Provider reminders on chart plus client education plus waiting room poster plus client reminders plus increased access (120 participants) versus; 2 Provider reminders on chart plus client education plus poster (123); 3 Previous usual care | Influenza, 1 versus 2 = 22% change (p = 0.002); 1 versus 3 = 44%; 2 versus 3 = 22%
Oeffinger Ref. 16 Time not reported | Nonrandomized trial, greatest suitability, fair | McLennan County, Texas; family practice residency program in hospital and clinic; clients - aged <1 year with 35%-39% adolescent mothers; 28%-36% Hispanic, 33%-47% black | 1 Client education at clinic plus client reminder letter (nonspecific) 2 months after birth versus; 2 Comparison group of usual care | Up-to-date with 3 doses of DTP/3 OPV by 12 months, 1 versus 2 = -4% change (p = 0.41)
O'Sullivan Ref. 17 Time not reported | Randomized trial, greatest suitability, fair | Eastern United States; large urban teaching hospital; target population - maternal aged <17 years; 100% black; low socioeconomic status | 1 Education and rigorous follow-up relating to family planning, parenting behaviors, return to school, health education, recall phone calls/letters, client-held vaccination records; lower costs versus; 2 Usual care | Children aged 18 months, 1 versus 2 = 15% change in up-to-date vaccination coverage (p < 0.02); mothers, clinic attendance and repeat pregnancy rates better in intervention group; return to school and emergency room use did not differ
Pierce Ref. 18 1989 (pre) 1993 (post) | Nonrandomized trial, greatest suitability, fair | Albuquerque, New Mexico; public health clinics; clients - children aged <12 months; 29%-70% Hispanic; most of remainder, white; 34% below poverty level | 1 Implementation of "Standards for Pediatric Vaccination Practices;" including evening and Saturday clinic hours plus client and provider education plus client reminders plus community involvement and outreach (846 participants pre, 309 post) versus; 2 Usual care (753 pre, 138 post) | Dropout, late start, and missed opportunities declined at intervention site relative to comparison; 3 DTP/2 OPV, 1 versus 2 = 17% increase at 7 months and 24% at 12 months (significance not tested because whole population included)
Turner Ref. 19 1984 | Nonrandomized trial, greatest suitability, fair | Philadelphia, Pennsylvania; internal medicine resident physician clinic; providers - junior and senior resident physicians; clients - adults, mean age 60-62 years; urban; 69%-78% female; low socioeconomic status | 1 Computerized provider reminders (103 charts audited) versus; 2 Written client educational materials plus questionnaire reviewed by provider (86 charts audited) versus; 3 Both (64 charts audited) versus; 4 Prior usual care for all groups (Total 39 resident physicians) | Td was <10% all groups pre and post and had not improved 1 year later; other preventive care significantly improved in 3 versus 4; physician knowledge by questionnaire increased (nonsignificant)

##### References

Etkind P, Simon M, Shannon S, et al. Impact of the Medicare Influenza Demonstration Project on influenza vaccination in a county in Massachusetts, 1988-1992. J Community Health. 1996;21:199-209. [pmid: 8726210].
Holtmann AG. Economics of U.S. immunization policy. In: Pauly MV, Robinson CA, Sepe SJ, et al. eds. Supplying vaccine: an economic analysis of critical issues. Washington, DC: IOS press; 1996:153-73.
Macdonald H, Roder D. Planning, implementation and evaluation of an immunization promotion campaign in South Australia. Hygiene. 1985;4:13-7.
Ohmit SE, Furumoto-Dawson A, Monto AS, Fasano N. Influenza vaccine use among an elderly population in a community intervention. Am J Prev Med. 1995;11:271-6. [pmid: 7495605].
Paunio M, Virtanen M, Peltola H, et al. Increase of vaccination coverage by mass media and individual approach: intensified measles, mumps, and rubella prevention program in Finland. Am J Epidemiol. 1991;133:1152-60. [pmid: 2035518].
Waterman SH, Hill LL, Robyn B, et al. Model immunization demonstration for preschoolers in an inner-city barrio, San Diego, California, 1992-94. Am J Prev Med. 1996;12(Suppl 1):8-13. [pmid: 8874698].
Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
Dickey LL, Petitti D. Patient-held minirecord to promote adult preventive care. J Fam Pract. 1992;34:457-63. [pmid: 1556540].
Elangovan S, Kallail KJ, Vargo G. Improving pneumococcal vaccination rates in an elderly population by patient education in an outpatient clinic. J Am Board Fam Pract. 1996;9:411-3. [pmid: 8923398].
Elster AB, Lamb ME, Tavare J, Ralston CW. Medical and psychosocial impact of comprehensive care on adolescent pregnancy and parenthood. JAMA. 1987;258:1187-92. [pmid: 3626002].
Herman CJ, Speroff T, Cebul RD. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. 1994;42:1154-9. [pmid: 7963201].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Lukasik MH, Pratt G. Telephone: an overlooked technology for prevention in family medicine. Canad Fam Physician. 1987;33:1997-2001.
Oeffinger KC, Roaten SP, Hitchcock MA, Oeffinger PK. Effect of patient education on pediatric immunization rates. J Fam Pract. 1992;35:288-93. [pmid: 1517726].
O'Sullivan AL, Jacobsen BS. Randomized trial of a health care program for first-time adolescent mothers and their infants. Nurs Res. 1992;41:210-5. [pmid: 1408861].
Pierce C, Goldstein M, Suozzi K, Gallaher M, Dietz V, Stevenson J. Impact of the standards for pediatric immunization practices on vaccination coverage levels. JAMA. 1996;276:626-30. [pmid: 8773635].
Turner BJ, Day SC, Borenstein B. A controlled trial to improve delivery of preventive care: physician or patient reminders. J Gen Intern Med. 1989;4:403-9. [pmid: 2677271].

#### Table B-3 Vaccination Requirements for Child Care, School, and College Attendance Recommended

Table B-3 Vaccination Requirements for Child Care, School, and College Attendance Recommended

Table B-3 Vaccination Requirements for Child Care, School, and College Attendance Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Vaccination Laws for School Attendance on Disease Rates
CDC Ref. 11979-80 | Cross-sectional study, least-suitable, fair | United States nationwide; target population not described | 1 "Comprehensive" laws requiring documentation of immunity for entry into all grades (35 states) versus; 2 School entry laws requiring immunity only at entry into kindergarten or first grade (14 states) | Of 15 states with high incidence of measles, 9 had only school entry laws; of 37 states with low incidence of measles, 11 had only school entry laws (p < 0.05)
Chaiken Ref. 21983 | Cross-sectional study, least-suitable, fair | New Jersey; children aged 5-19 years, grades K-12 | 1 Law requiring students aged <7 years to be vaccinated against mumps versus; 2 Comparison group of usual care (Total study population, 3,250 participants) | 96% of children covered by law versus 61% not covered had "documented immunity"; 25% of children not covered by law had mumps versus 3% of children covered by law (statistically significant)
Robbins Ref. 31977-78 | Cross-sectional study, least-suitable, fair | United States nationwide; children aged <18 years | 1 Presence, type, and enforcement of state school vaccination laws versus; 2 Comparison group of usual care (54 vaccination project areas) | Areas with low versus than high incidence more likely to have laws requiring measles vaccinations for all children, 46% versus 0 (p < 0.025); more likely to enforce exclusion from school, 77% versus 0 (p < 0.001)
Van Loon Ref. 41995 | Before/after study, least-suitable, fair | United States nationwide; children aged 5-19 years, grades K-12 | 1 Partial law requiring certain students to receive mumps vaccination versus; 2 Comprehensive law requiring all students to receive mumps vaccination versus; 3 Comparison group of usual care (50 states) | Mumps incidence cases/100,000, 1 = 5.4 %; 2 = 3.8; 3 = 9.4 (statistical significance not reported)
Effects of Vaccination Laws for School Attendance on Immunity
Nelson Ref. 5Schum Ref. 61979-87 | Time-series study, moderate suitability, fair | Milwaukee, Wisconsin; clinics; clients - aged 9-15 years; 75%-82% black; urban; low socioeconomic status | 1 Enactment and enforcement of school law in 1980-1 requiring vaccination versus; 2 Prior usual care (1979-81, 481 participants; 1985-7, 341) | Rubella susceptibility, declined from 22% in 1979 to 5% in 1981 (p < 0.001); rubella susceptibility, increased from 4% in 1985 to 25% in 1987 (significant)
Effects of Vaccination Laws for School Attendance on Coverage
Carlson Ref. 71983-84 | Before/after study, least-suitable, fair | Ontario, Canada; children aged 5-17 years, grades K-12 | 1 Law requiring school attendees aged <18 years to be vaccinated against diphtheria, tetanus, polio, measles, and rubella versus; 2 Comparison group of usual care (Size of target population not reported) | Single-antigen measles, tetanus, diphtheria, rubella, polio, mumps coverage, average 5%, range 3%-9% (statistical significance not reported); effects larger in high school students, 1 versus 2 = 35% change
Chaiken Ref. 21983 | Cross-sectional study, least-suitable, fair | New Jersey; children aged 5-19 years, grades K-12 | 1 Law requiring students aged <7 years to be vaccinated against mumps versus; 2 Comparison group of usual care (Total study population, 3,250 participants) | 96% of children covered by law versus 61% not covered had "documented immunity"; 25% of children not covered by law had mumps versus 3% of children covered by law (significant)
Scheiber Ref. 81979-87 | Time-series study, moderate suitability, fair | California; children aged 5-6 years | 1 School entry vaccination laws enacted in 1977 and enforced in 1986 versus; 2 Prior usual care (Size of target population not provided) | DTP/OPV/MMR (4:3:2 doses, respectively), 15% change (statistical significance not reported)
Effects of Vaccination Laws for Child Care Attendance on Disease Rates
Schulte Ref. 91987-91 | Before/after study, least-suitable, fair | New York State; child care centers; children aged <5 years | 1 State requirement for Hib vaccinations in child care centers enacted in 1990 but never enforced versus; 2 Comparison group of prior care (Study population not reported) | 1 versus 2, Hib incidence cases/100,000 in New York State, 30 versus 3; in child care centers 31 versus 9 (statistical testing not reported); rate of decline of incidence in child care centers was greater than rate of decline in all New York State children (p < 0.002)
Effects of Vaccination Laws for College Attendance on Disease Outbreaks
Baughman Ref. 10 1988-91 | Retrospective cohort study, moderate suitability, fair | United States nationwide; two- and four-year colleges; target population - college students; students not otherwise described | 1 Prematriculation vaccination requirement by state law versus; 2 Prematriculation vaccination requirement by regent's policy or no requirement. (880 colleges) | 1 versus 2, in multivariate analysis relative risk of outbreaks = 0.3, CI = 0.11%-0.84%

##### References

Centers for Disease Control and Prevention. School immunization requirements for measles-United States, 1981. MMWR. 1981;30:158-60. [pmid: 6789068].
Chaiken BP, Williams NM, Preblud SR, Parkin W, Altman R. Effect of a school entry law on mumps activity in a school district. JAMA. 1987;257:2455-8. [pmid: 3573244].
Robbins KB, Brandling-Bennett AD, Hinman AR. Low measles incidence: association with enforcement of school immunization laws. Am J Public Health. 1981;71:270-4. [pmid: 7468859].
van Loon FPL, Holmes SJ, Sirotkin BI, et al. Mumps surveillance-United States, 1988-1993. In: CDC Surveillance Summaries, August 11, 1995. MMWR. 1995;44(No. SS-3):1-14.
Nelson DB, Layde MM, Chatton TB. Rubella susceptibility in inner-city adolescents: the effect of a school immunization law. Am J Public Health. 1982;72:710-3. [pmid: 7091461].
Schum TR, Nelson DB, Duma MA, Sedmak GV. Increasing rubella seronegativity despite a compulsory school law. Am J Public Health. 1990;80:66-9. [pmid: 2293805].
Carlson JAK, Lewis CA. Effect of the immunization program in Ontario schools. CMAJ. 1985;133:215-6. [pmid: 4016629].
Scheiber M, Halfon N. Immunizing California's children: effects of current policies on immunization levels. West J Med. 1990;153:400-5. [pmid: 2244375].
Schulte EE, Birkhead GS, Kondracki SF, Morse DL. Patterns of Haemophilus influenzae type b invasive disease in New York sate, 1987 to 1991: the role of vaccination requirements for day-care attendance. Pediatrics. 1994;94 (6 Pt 2):1014-6. [pmid: 7971041].
Baughman AL, Williams WW, Atkinson WL, Cook LG, Collins M. Impact of college prematriculation immunization requirements on risk for measles outbreaks. JAMA. 1994;272:1127-32. [pmid: 7933326].

#### Table B-4 Communitywide Education Only Insufficient Evidence

Table B-4 Communitywide Education Only Insufficient Evidence

Table B-4 Communitywide Education Only Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Paunio Ref. 11982-86 | Time-series study, moderate suitability, fair | Finland; communitywide; target population - aged birth-11 years | 1 Registry plus mass-media reporting of local data regarding vaccination coverage plus provider reminders plus parent reminders versus; 2 Usual care before registry | MMR, 1 versus 2 = 8% change (no significance testing) Fitted weekly time series models of number of MMR delivered 1 versus 2, no effect on number of vaccinations administered to children aged 14-18 months; mass-media might have increased vaccinations administered to children aged 6 years; all three interventions increased numbers of children aged 6 years who received first MMR

##### References

Paunio M, Virtanen M, Peltola H, et al. Increase of vaccination coverage by mass media and individual approach: intensified measles, mumps, and rubella prevention program in Finland. Am J Epidemiol. 1991;133:1152-60. [pmid: 2035518].

#### Table B-5 Clinic-Based Education Only Insufficient Evidence

Table B-5 Clinic-Based Education Only Insufficient Evidence

Table B-5 Clinic-Based Education Only Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Clayton Ref. 1Time not reported | Before/after study, least-suitable, fair | Nashville, Tennessee; resident clinic and 6 private practices; parents 98% female; mean age 29 years (pre) and 30 years (post); 56%-60% work outside home; 40% -46% have college degrees | 1 "Vaccination Information Statements" (198 participants) versus; 2 Usual care (236) | 1 versus 2 = increased numbers of facts recalled (p < 0.0001); 40% increase in those reported wanting to have child vaccinated (p < 0.0001); 16% increase in persons who thought they had received too much material
Herman Ref. 21989-90 | Randomized trial, greatest suitability, good | Cleveland, Ohio; academic clinical organization; clients - aged >65 years; 67% female, predominantly white | 1 Standing orders/client education/provider education (prevention team) (387 participants) versus; 2 Client/provider education (389) versus; 3 Provider education (426) | Influenza, 1 versus 3 = 13% change; pneumococcal, 19% (significant); 2 versus 3 = 3% influenza and 2% pneumococcal (nonsignificant)
Lieu Ref. 31992-93 | Before/after study, least-suitable, good | Alamo and San Ramon, California; multispecialty medical group; clients - upper-middle socioeconomic status; predominantly white and college educated | 1 "Vaccination Information Statements" (180 participants) versus; 2 Usual care (218) | 1 versus 2 produced no statistically significant change in parental belief that they had enough information to make informed decisions regarding vaccinations or in parental anxiety and produced small but statistically significant declines in parental comfort regarding vaccinations

##### References

Clayton EW, Hickson GB, Miller CS. Parents' responses to vaccine information pamphlets. Pediatrics. 1994;93:369-72. [pmid: 8115193].
Herman CJ, Speroff T, Cebul RD. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. 1994;42:1154-9. [pmid: 7963201].
Lieu TA, Glauber JH, Fuentes-Afflick E, Lo B. Effects of vaccine information pamphlets on parents' attitudes. Arch Pediatr Adolesc Med. 1994;148:921-5. [pmid: 8075734].

#### Table B-6 Client or Family Incentives Insufficient Evidence

Table B-6 Client or Family Incentives Insufficient Evidence

Table B-6 Client or Family Incentives Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Browngoehl Ref. 1Kennedy Ref. 21992-93 | Retrospective cohort study; moderate suitability; fair | Philadelphia, Pennsylvania; Medicaid managed care group; clients - children aged 30-35 months (control group) and 18-24 months (study group); low socioeconomic status | 1 Tracking and reminders plus provider education and incentives plus parent education and incentives plus transportation assistance plus home visits (1,254 participants) versus; 2 Control group of older children (1,257) | 4 DTP/3 OPV/1 MMR at age 35 months, 1 versus 2 = 7% change (p < 0.05); 4 DTP/3 OPV/1 MMR/1 Hib at age 35 months, 1 versus 2 = 2% change (nonsignificant) Higher coverage in children who received home visits (significance not given)
Moran Ref. 31991 | Randomized trial, greatest suitability, fair | Boston, Massachusetts; community health center; clients - adults, mean age 66 years; urban; 33%-35% male; low socioeconomic status | 1 Mailed client reminders versus; 2 Lottery-type client incentive versus; 3 Both versus; 4 Comparison group of usual care (Total study population, 797 participants) All groups received walk-in vaccinations, free vaccinations, and health fair | Influenza, 1 versus 4 = 16% change; 2 versus 4 = 9%; 3 versus 4 = 6%; multivariate analysis odds ratios, 1 = 2.29% (CI = 1.45%-3.61%, 2 = 1.68% (CI = 1.05%-2.68%, 3 = 1.41% (CI = 0.88%-2.27%)
Yokley Ref. 4Time not reported | Group randomized trial (by family), greatest suitability, fair | Akron, Ohio; public health clinic; clients - aged <5 years, mean 37 months; 50% female; 64% white | 1 Mailed general client reminder (195 participants) versus; 2 Mailed specific client reminder (190) versus; 3 Mailed specific client reminder plus special off hours clinics (185) versus; 4 Mailed specific client reminder plus parent incentive lottery (183) versus; 5 Comparison group of usual care (191) | Vaccinated with at least 1 antigen after 3 months, 1 versus 5 = 3% change (nonsignificant); 2 versus 5 = 13% (nonsignificant); 3 versus 5 = 16% (significant); 4 versus 5 = 18% (significant)

##### References

Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
Moran WP, Nelson K, Wofford JL, Velez R, Case LD. Increasing influenza immunization among high-risk patients: education or financial incentive. Am J Med. 1996;101:612-20. [pmid: 9003108].
Yokley JM, Glenwick DS. Increasing the immunization of preschool children: an evaluation of applied community interventions. J Appl Behav Anal. 1984;17:313-25. [pmid: 6439714].

#### Table B-7 Client-Held Medical Records Insufficient Evidence

Table B-7 Client-Held Medical Records Insufficient Evidence

Table B-7 Client-Held Medical Records Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Dickey Ref. 11988-99 | Nonrandomized trial, greatest suitability, fair | San Francisco, California; family practice residency clinic; clients - mean age 55 years; urban; 49%-55% Spanish speaking | 1 "Health diary" regarding vaccinations and other preventive services given to providers and clients plus posters in waiting room (200 participants) plus client education delivered by nursing staff versus; 2 "Health diary" given to providers | Influenza, 1 versus 2 = 15% change (significant) at 6 months and -7% at 18 months; Td, 1 versus 2 = 4% at 6 months and 7% (significant) at 18 months; pneumococcal, 1 versus 2 = -1% at 6 months and 16% at 18 months; performance in 8 preventive services, 1 versus 2 = 11% change at 6 months (p < 0.001) and 9% at 18 months (p = 0.006)
Dietrich Ref. 21984-86 | Randomized trial, greatest suitability, fair | New Hampshire; small-town community practice; clients - aged >65 years; 67%-68% female | 1 Personal prevention checklist (influenza, blood pressure, cancer) plus questionnaires regarding personal characteristics and recent preventive care (59 participants) versus; 2 Reminder letter for influenza vaccination (55) | Influenza, >45% vaccinated in both groups (nonsignificant); cancer screening, 1 versus 2 = 16% change (p < 0.05); blood pressure, measured >90% of groups
O'Sullivan Ref. 3Time not reported | Randomized trial, greatest suitability, fair | Eastern United States; large urban teaching hospital; maternal aged <17 years; 100% black; low socioeconomic status | 1 Education and rigorous follow-up relating to family planning, parenting behaviors, return to school, health education, recall phone calls/letters, client-held vaccination records, lower costs versus; 2 Usual care | Children aged 18 months, 1 versus 2 = 15% change in up-to-date vaccination coverage (p < 0.02); mothers, clinic attendance and repeat pregnancy rates better in intervention group; return to school and emergency room use did not differ
Turner Ref. 41987-88 | Randomized trial, greatest suitability, fair | Greenville, North Carolina; resident physician clinic, East Carolina School of Medicine; clients - 60% black, mixed urbanistically, otherwise, target population incompletely described | 1 Client-held mini record plus provider reminders (177 participants) versus; 2 Provider reminders (246) | Influenza, 1 versus 2 = 18% (p < 0.002); pneumococcal, 1 versus 2 = -2% (p = 0.34); significant increase occurred in most other preventive measures

##### References

Dickey LL, Petitti D. Patient-held minirecord to promote adult preventive care. J Fam Pract. 1992;34:457-63. [pmid: 1556540].
Dietrich AJ, Duhamel M. Improving geriatric preventive care through a patient-held checklist. Fam Med. 1989;21:195-8. [pmid: 2744287].
O'Sullivan AL, Jacobsen BS. Randomized trial of a health care program for first-time adolescent mothers and their infants. Nurs Res. 1992;41:210-5. [pmid: 1408861].
Turner RC, Waivers LE, O'Brien K. Effect of patient-carried reminder cards on the performance of health maintenance measures. Arch Intern Med. 1990;150:645-7. [pmid: 2310284].

#### Table B-10-8 Reducing Out-of-Pocket Costs Strongly Recommended

Table B-10-8 Reducing Out-of-Pocket Costs Strongly Recommended

Table B-10-8 Reducing Out-of-Pocket Costs Strongly Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Reducing Out-of-Pocket Vaccination Costs Only
Combs Ref. 1 1993-94 | Before/after study, least-suitable, fair | Durham, North Carolina; Duke University Medical Center clinics; clients - infants | 1 Free vaccination through continuity clinic (335 participants) versus; 2 Prior usual care that involved obtaining hepatitis B vaccinations 2 and 3 at health department (376 participants) | Hepatitis B, 3 doses by time of third DTP, 1 versus 2 = 29% change (p < 0.001); any dose during the study period, 1 versus 2 = 14% change (p < 0.001)
Holtman Ref. 2 1989 and 1990 | Cross-sectional study, least-suitable; fair | United States nationwide; communitywide; aged 2 years, otherwise, target population not well-described | 1 Presence of education and tracking systems or free vaccinations as reported by states to GAO or to CDC versus; 2 Lack of those interventions as reported by states | By ordinary least squares regression, states with universal vaccine provision programs have vaccination coverages among children aged 2 years that are higher than states with neither a universal vaccination provision plan or a vaccination replacement plan, all else equal; 10% difference, p = 0.11, CDC data; 9% difference, p = 0.035, GAO data Presence of an education and tracking system had variable relationships to vaccination coverage (0% difference, p = 0.99, CDC data; 9% difference, p = 0.011, GAO data)
Ives Ref. 3 Lave Ref. 4 1989-91 | Randomized trial, greatest suitability, fair | Pennsylvania; 5 rural counties hospitals/clinics; clients - aged 65-79 years; 57% female | 1 Free vaccinations from hospital versus; 2 Free vaccinations from provider versus; 3 Comparison group of usual care (Total study population, 1,989 participants) All groups received exam/vaccination assessment | Influenza, 1 versus 3 = 9% change (p < 0.0001); 2 versus 3 = 15% (p < 0.0001)
Lurie Ref. 5 1974-82 | Randomized trial, greatest suitability, fair | Cities in Ohio, Washington, Massachusetts; target population - adults and children aged <62 years; mixed urbanistically; mixed socioeconomic status | 1 Insurance coverage with free vaccination versus; 2 Insurance coverage with copays (Total study population, 3,823 participants) | Percentage of persons filing claims for DTP/MMR (children) or influenza/Td (adults), 1 versus 2 = 10% change in children (significant); 1 versus 2 = 8% in adults (significant)
Rodewald Ref. 6 1991-93 | Before/after study, least-suitable, fair | Upstate New York; clinics and communitywide; clients - aged birth-6 years, 48% female, 85% white, low socioeconomic status | 1 Insurance plan that provided coverage for vaccinations at <222% poverty versus; 2 Prior insurance coverage (Total study population, 2,232 participants) | Up-to-date with DTP/OPV/MMR for children aged 1-5 years, 1 versus 2 = 5% change (p < 0.001) Referral to public health clinics decreased from 0.06 to 0.02 visits /year/child (p < 0.01) and use of private providers increased from 0.46 to 0.52 visits/child/year (p < 0.01)
Taylor Ref. 7 Early 1990s | Other designs with concurrent comparison groups, greatest suitability, fair | Idaho, Massachusetts, Rhode Island, Vermont, Washington, Colorado, New Jersey, New York, Oregon, South Carolina, Utah; private pediatric offices; clients - aged 2 or 3; otherwise, not described | 1 State-sponsored universal purchase program (7 providers); versus; 2 Usual care (8 providers) (Client charts evaluated, 857-977) | 4 DTP/3 OPV/1 MMR at age 2 years, 1 versus 2 = -1% change (p = 0.774) Pediatricians in nonuniversal purchase states reported more likely to refer children elsewhere for immunization 7/8 versus 2/7 (p = 0.04)
Zimmerman Ref. 8 Time not reported | Cross-sectional study, least-suitable, fair | Minnesota; clinics/offices of family practitioners and pediatricians; clients - aged <7 years, mixed socioeconomic | 1 No insurance coverage versus; 2 Medicaid versus; 3 Private insurance (37 providers; 507 client records) | Age of receipt of third DTP and MMR for children with insurance was closer to recommended age than for children with no insurance; significant for third DTP; nonsignificant for MMR Clients of providers who referred clients for vaccinations were more likely to have delays
Effects on Coverage of Reducing Out-of-Pocket Vaccination Costs in Combination with Other Interventions
Etkind Ref. 9 1988-92 | Nonrandomized group trial, greatest suitability, fair | Essex and Worcester Counties, Massachusetts; communitywide; Essex county target population - 90% urban; aged >65 years; predominantly white; socioeconomic status not reported. | 1 Multiple approaches to promoting influenza vaccination to target population plus provider education plus administration fee to providers (91,621 Medicare Part B enrollees) versus; 2 Baseline in intervention county (number not provided) versus; 3 Usual practice in comparison county (95,234 Medicare Part B enrollees) | 1 versus 2 = 29% change (statistical significance not provided); 1 versus 3, doses distributed in Essex County increased from ~25,000/year before to ~57,400/year after versus no change in comparison county
Hutchins Ref. 10 1991-93 | Randomized trial, highly suitable, fair | Chicago, Illinois; WIC sites; clients - aged <5 years; 53%-98% black; 1%-42% Hispanic; urban; low socioeconomic status | 1 Assessment of immunization status and education, plus voucher restriction plus referral to on-site clinic, off-site clinic, or on-site nurse; free vaccinations offered to all study participants versus; 2 Comparison group of usual care (Total, 27,596 children in study; 300 aged 13-35 months evaluated in each group) | DTP/OPV/MMR (4:3:1 doses, respectively) at 24 months, 1 versus 2 = 34% change (p < 0.05);
Moran Ref. 11 1990 | Randomized trial, greatest suitability, fair | Location not reported; community health center; clients - adults; urban; 61% female | 1 Single client reminder letter (135 participants) versus; 2 Two client reminder letters (138) versus; 3 Comparison group of usual care (136) Vaccination available free and without appointment | Influenza, 1 versus 3 = 2% change (nonsignificant); 2 versus 3 = -8% (nonsignificant)
Nexøe Ref. 12 1995 | Randomized trial, greatest suitability, fair | Denmark; general practices; clients - adults aged >65 years; 60% female | 1 Mailed client reminders (195 participants) versus; 2 Mailed client reminder plus free vaccination (195) versus; 3 Comparison group of usual care (195) | Influenza, 1 versus 3 = 24% change; 2 versus 3 = 47%
Ohmit Ref. 13 1989-92 | Time-series study, moderate suitability, fair | Seven counties in southwest Michigan; clinics and offices; clients - aged >65 years; otherwise, target population not described | 1 Communitywide education of physicians and clients plus free vaccination plus provider education plus client education plus mailed postcard client reminders plus outreach in senior centers (evaluated 1,315 and 1,663 participants in 1990-91 and 1991-92, respectively) versus; 2 Prior usual care (client numbers not given) | Influenza, 1 versus 2 = 16% change (statistical significance not reported)
O'Sullivan Ref. 14 Time not reported | Randomized trial, greatest suitability, fair | Eastern United States; large urban teaching hospital; target population - maternal aged <17 years; 100% black; low socioeconomic status | 1 Education and rigorous follow-up relating to family planning, parenting behaviors, return to school, health education, recall phone calls/letters, client-held vaccination records; lower costs versus; 2 Usual care | Children aged 18 months, 1 versus 2 = 15% change in up-to-date vaccination coverage (p < 0.02); mothers, clinic attendance and repeat pregnancy rates better in intervention group; return to school and emergency room use did not differ
Satterthwaite Ref. 15 Time not reported | Randomized trial, greatest suitability, fair | Aukland, New Zealand; general practices; clients - aged >65 years; otherwise, target population not described | 1 Personal client reminder letter (931 participants) versus; 2 Same plus free vaccination offered in letter (930) versus; 3 Comparison group of usual care (930) | Influenza, 1 versus 3 - 10% change (p < 0.001); 2 versus 3 = 28% (p < 0.001)
Szilagyi Ref. 16 1994 | Prospective cohort study, greatest suitability, fair | New York City (Manhattan and the Bronx); 2 emergency departments; clients - aged birth-6.9 years; urban; 52%-53% male; low socioeconomic status | 1 Clients screened in emergency department and offered vaccination plus vaccinations provided at no cost (484) versus; 2 Prior usual care | Up-to-date with DTP/OPV/MMR/Hib/Hepatitis B, 1 versus 2 = 11% change (p < 0.001) at 1 day and 2% (nonsignificant) after 6 months in Manhattan; 1 versus 2 = 8% (p < 0.05) at 1 day and 9% (nonsignificant) at 6 months in Bronx
Effects of Reducing Out-of-Pocket Vaccination Costs on Vaccine Availability and Referral
Arnold Ref. 17 1990 | Cross-sectional survey, least-suitable, fair | Milwaukee, Wisconsin; pediatric clinics; clients - children; otherwise, not well-described | 1 Traditional private insurance versus; 2 Managed care versus; 3 Medicaid versus; 4 No insurance coverage (202 physicians) | DTP/OPV/MMR/Hib vaccination less likely to be provided to uninsured clients (p < 0.01) No differences in vaccination provision between managed care or traditional private insurance
Mainous Ref. 18 Hueston Ref. 19 1993 | Other designs with concurrent comparison groups (matched cross-sectional survey of physicians), greatest suitability, good | Washington, Oregon, North Dakota, South Dakota, New Hampshire, Delaware; family practice clinics; clients not described | 1 Practitioners in states that provide free vaccinations for Medicaid clients versus; 2 Practitioners in states that do not provide free vaccinations for Medicaid clients (553 providers) | Practices in free-vaccination states were more likely to offer vaccinations to Medicaid clients; 1 versus 2 = 17% (reported statistically significant). Largest differences in rural practices and small communities.
Ruch-Ross Ref. 20 1992 | Cross-sectional survey, least-suitable, fair | United States nationwide; pediatricians; 87% metropolitan, 12% nonmetropolitan, 1% rural | 1 State programs that provide free vaccinations versus; 2 Usual care in comparison states (1,246 of 1,600 pediatricians responded to survey) | Presence and type of state program providing free vaccinations was significantly associated with likelihood that children would be referred. Odds of referral if state provides some vaccines free of charge 3.7, odds of referral if state provides no free vaccinations 6.7; relative to states providing all vaccines free. Costs of vaccinations were leading reported cause of referrals
Zimmerman Ref. 21 1995 | Other designs with concurrent comparison groups (matched cross-sectional survey), greatest suitability, good | United States; pediatrician and family practice offices; 86% urban | 1 Free vaccinations for specific child populations versus; 2 Usual care (1,236 of 2,100 physicians surveyed) | Practices with free vaccinations reported to refer less often. Referral rates for clients who were uninsured and unable to pay was 90% in states not providing free vaccinations versus 44% in states providing free vaccinations (p < 0.001)

##### References

Combs SP, Walter EB, Drucker RP, Clements DA. Removing a major barrier to universal hepatitis B immunization in infants. Arch Pediatr Adolesc Med. 1996;150:112-4. [pmid: 8541998].
Holtmann AG. Economics of U.S. immunization policy. In: Pauly MV, Robinson CA, Sepe SJ, et al. eds. Supplying vaccine: an economic analysis of critical issues. Washington, DC: IOS press; 1996:153-74.
Ives DG, Lave JR, Traven ND, Kuller LH. Impact of Medicare reimbursement on influenza vaccination rates in the elderly. Prev Med. 1994;23:134-41. [pmid: 8047518].
Lave JR, Ives DG, Traven ND, Kuller LH. Evaluation of a health promotion demonstration program for the rural elderly. Health Serv Res. 1996;31:261-81. [pmid: 8698585].
Lurie N, Manning WG, Peterson C, Goldberg GA, Phelps CA, Lillard L. Preventive care: do we practice what we preach?. Am J Public Health. 1987;77:801-4. [pmid: 3592032].
Rodewald LE, Szilagyi PG, Holl J, Shone LR, Zwanziger J, Raubertas RF. Health Insurance for low-income, working families: impact on the delivery of immunizations to preschool children. Arch Pediatr Adolesc Med. 1997;151:798-803. [pmid: 9265881].
Taylor JA, Darden PM, Slora E, Hasemeier CM, Asmussen L, Wasserman R. Influence of provider behavior, parental characteristics, and a public policy initiative on the immunization status of children followed by private pediatricians: a study from pediatric research in office settings. Pediatrics. 1997;99:209-15. [pmid: 9024448].
Zimmerman RK, Janosky JE. Immunization barriers in Minnesota private practices: the influence of economics and training on vaccine timing. Family Practice Research Journal. 1993;13:213-24. [pmid: 8296585].
Etkind P, Simon M, Shannon S, et al. Impact of the Medicare Influenza Demonstration Project on influenza vaccination in a county in Massachusetts, 1988-1992. J Community Health. 1996;21:199-209. [pmid: 8726210].
Hutchins SS, Rosenthal J, Eason P, et al. Effectiveness and cost-effectiveness of linking the special supplemental program for women, infants and children (WIC) and immunization activities, 1997. American Journal of Public Health Policy 1999:20(4). In press.
Moran WP, Nelson K, Wofford JL, Velez R. Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med. 1992;7:535-7. [pmid: 1403212].
Nexøe J, Kragstrup J, Rønne T. Impact of postal invitations and user fee on influenza vaccination rates among the elderly: a randomized controlled trial in general practice. Scand J Prim Health Care. 1997;15:109-12. [pmid: 9232713].
Ohmit SE, Furumoto-Dawson A, Monto AS, Fasano N. Influenza vaccine use among an elderly population in a community intervention. Am J of Prev Med. 1995;11:271-6. [pmid: 7495605].
O'Sullivan AL, Jacobsen BS. Randomized trial of a health care program for first-time adolescent mothers and their infants. Nurs Res. 1992;41:210-5. [pmid: 1408861].
Satterthwaite P. Randomized intervention study to examine the effect on immunization coverage of making influenza vaccine available at no cost. N Z Med J. 1997;110:58-60. [pmid: 9076288].
Szilagyi PG, Rodewald LE, Humiston SG, et al. Effect of 2 urban emergency department immunization programs on childhood immunization rates. Arch Pediatr Adolesc Med. 1997;151:999-1006. [pmid: 9343010].
Arnold PJ, Schlenker TL. Impact of health care financing on childhood immunization practices. American Journal of Diseases of Children. 1992;146:728-32. [pmid: 1595629].
Mainous AG III, Hueston WJ. Medicaid free distribution programs and availability of childhood immunizations in rural practices. Fam Med. 1995;27:166-9. [pmid: 7774774].
Hueston WJ, Mainous AG III, Farrell JB. Childhood immunization availability in primary care practices: effects of programs providing free vaccines to physicians. Arch Fam Med. 1994;3:605-9. [pmid: 7921296].
Ruch-Ross HS, O'Connor KG. Immunization referral practices of pediatricians in the United States. Pediatrics. 1994;94:508-12. [pmid: 7936861].
Zimmerman RK, Medsger AR, Ricci EM, Raymund M, Mieczkowski TA, Grufferman S. Impact of free vaccine and insurance status on physician referral of children to public vaccine clinics. JAMA. 1997;278:996-1000. [pmid: 9307347].

#### Table B-9 Expanding Access in Healthcare Settings Strongly Recommended as Part of Multicomponent Intervention Insufficient Evidence When Used Alone

Table B-9 Expanding Access in Healthcare Settings Strongly Recommended as Part of Multicomponent Intervention Insufficient Evidence When Used Alone

Table B-9 Expanding Access in Healthcare Settings Strongly Recommended as Part of Multicomponent Intervention Insufficient Evidence When Used Alone

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Expanding Access in Healthcare Settings Only
Nicholson Ref. 1 1984 | Cross-sectional study, least-suitable, fair | Trent, United Kingdom; general practitioners; clients - aged >65 years; otherwise, not well-described | 1 Practice policies including any of following: home-bound clients to be vaccinated at home, client reminders, or special vaccination clinics versus; 2 Lack of policies (Study group total, 127 general practitioners surveyed) | Influenza, 1 versus 2 = 10% change (p < 0.05) for home vaccination; other policy parameters found significant increases Influenza, 1 versus 2 = 7% change (p < 0.05) for regular or special immunization clinics
Rodewald Ref. 2 1990-91 | Randomized trial, greatest suitability, fair | Rochester, New York; emergency departments; primary care sites; clients - aged 6-36 months, mean 18 months; urban; 55%-59% female; 43%-48% black; low socioeconomic status | 1 Provider reminders by mail (610 participants) versus; 2 Vaccinations offered on-site at emergency departments (611) versus; 3 Comparison group of usual care (614) All children enrolled through emergency departments | Up-to-date with DTP/OPV/MMR/Hib, 1 versus 3 = no significant difference; 2 versus 3 = 8% change (p = 0.002) at 1 month, but 2 versus 3 = 3% (p = 0.2) at 12 months
Effects of Expanding Access in Healthcare Settings in Combination with Other Interventions
Browngoehl Ref. 3 Kennedy Ref. 4 1992-93 | Retrospective cohort study; moderate suitability; fair | Philadelphia, Pennsylvania; Medicaid managed care group; clients - children aged 30-35 months (control group) and 18-24 months (study group), low socioeconomic status | 1 Tracking and reminders plus provider education and incentives plus parent education and incentives plus transportation assistance plus home visits (1,254 participants) versus; 2 Control group of older children (1,257) | 4 DTP/3 OPV/1 MMR at age 35 months, 1 versus 2 = 7% change (p < 0.05); 4 DTP/3 OPV/1 MMR/1 Hib at age 35 months, 1 versus 2 = 2% change (nonsignificant) Higher coverage in children who received home visits (significance not given)
Elster Ref. 5 1983-84 | Nonrandomized trial, greatest suitability, fair | Utah; University of Utah school of medicine; mothers <19 years; 14%-22% of study population Hispanic; mixed socioeconomic status | 1 Adolescent mother and child program included nutrition and psychosocial assessments, medical care for mother-infant pairs, counseling, nutrition, and medical services, staff available nights and weekends versus; 2 Usual care for clients recruited from the other local WIC program | Up-to-date vaccination coverage among infants, 1 versus 2 = 13% change at 12 months and 17% at 26 months (p < 0.05 both comparisons); multiple nonvaccination outcomes also improved
Hutchison Ref. 6 Frank Ref. 7 1981-87 | Time-series study, moderate suitability; fair | Hamilton, Ontario; community clinic; clients - aged >65 years; urban; 66% female | 1 Mailed client reminder letter (273 participants) and associated drop-in clinics versus; 2 Prior usual care | Influenza, 1 versus 2 after 6 years = 35% change (statistical testing not reported)
Karuza Ref. 8 1990-92 Calkins Ref. 9 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart or client reminders or waiting room posters or provider education or standing orders or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Lukasik Ref. 10 1985 | Nonrandomized trial, greatest suitability, fair | London, Ontario; Victoria Family Medicine Center; clients - aged >65 years; otherwise, not well-described | 1 Provider reminders on chart plus client education plus waiting room poster plus client reminders plus increased access (120 participants) versus; 2 Provider reminders on chart plus client education plus poster (123) versus; 3 Previous usual care | Influenza, 1 versus 2 = 22% change (p = 0.002); 1 versus 3 = 44%; 2 versus 3 = 22%
Macdonald Ref. 11 1979-81 | Before/after study, least-suitable, fair | South Australia; communitywide; target population not described | 1 Provider education plus mass-media campaign plus dedicated vaccination clinics versus; 2 Usual care before campaign (Size of target population not provided) | Survey of a convenience sample found 19% could recall campaign without prompting (2/3 could recall with prompting); attendance for MMR in 1981 versus 1979-80 was 14% greater before the campaign and 90% greater after
Margolis Ref. 12 1989-90 | Nonrandomized trial, greatest suitability, fair | Minneapolis-St. Paul, Minnesota; staff model health maintenance organization; clients - aged >65 years; urban/suburban | 1 Standing orders, client reminder/recall, provider education, expanded access versus; 2 Usual care Two clinics in each group; outcomes assessed in 150 randomly chosen clients/clinic | Intervention clinic 1 versus comparison clinic 1 = 8% change; intervention clinic 2 versus comparison clinic 2 = 20%; post- versus prechange in intervention clinic 2 (significant, p = 0.01); changes in other clinics nonsignificant
Moran Ref. 13 1990 | Randomized trial, greatest suitability, fair | Location not reported; community health center; clients - adults; urban; 61% female | 1 Single client reminder letter (135 participants) versus; 2 Two client reminder letters (138) versus; 3 Comparison group of usual care (136) Vaccination available free and without appointment | Influenza, 1 versus 3 = 2% change (nonsignificant); 2 versus 3 = -8% (nonsignificant)
Nichol Ref. 14 1987 Nichol Ref. 15 1987-92 | Other designs with concurrent comparison groups, greatest suitability, time-series study, moderate suitability, both fair | Minneapolis, Minnesota, versus other midwestern cities; VA outpatient services; clients - veterans | 1 Standing orders, walk-in "flu-shot" clinics, provider reminders, vaccination stations in busy clinic areas, mailing to all outpatients (378 participants) versus; 2 Usual care at 3 other midwestern academic hospitals (997) | Influenza, 1 versus 2 = 26% change (p < 0.00001); time-series data found that coverage rates continued to increase for 5 years; additional 15% among all clients (p < 0.0001)
Nichol Ref. 16 1990 | Prospective cohort study, greatest suitability, fair | Minneapolis, Minnesota; VA hospital; clients - aged >65 years | 1 Standing orders and vaccination stations among inpatients versus; 2 Standing orders and provider reminders and walk-in "flu-shot" clinics and educational mailings among outpatients | Influenza, before intervention inpatient coverage <25% and outpatient coverage >60%; addition of policy for inpatients brought inpatient coverage to 79%, which did not differ significantly from outpatient levels
Pierce Ref. 17 1989 (pre) 1993 (post) | Nonrandomized trial, greatest suitability, fair | Albuquerque, New Mexico; public health clinics; aged <12 months; 70%-29% Hispanic; remainder predominately white; 34% below poverty level | 1 Implementation of "Standards for Pediatric Vaccination Practices" including evening and Saturday clinic hours plus client and provider education plus client reminders, community involvement and outreach (846 participants pre, 309 post) versus; 2 Usual care (753 pre, 138 post) | Dropout, late start, and missed opportunities declined at intervention site relative to comparison; 3 DTP/2 OPV, 1 versus 2 = 17% change at 7 months and 24% at 12 months (significance not tested because entire population included)
Szilagyi Ref. 18 1994 | Prospective cohort study, greatest suitability, fair | New York City (Manhattan and the Bronx); 2 emergency departments; aged birth-6.9 yrs; urban; 52%-53% male; low socioeconomic status | 1 Clients screened in emergency department and offered vaccination plus vaccinations provided at no cost (484 participants) versus; 2 Prior usual care | Up-to-date with DTP/OPV/MMR/Haemophilus influenzae type B/hepatitis B, 1 versus 2 = 11% change (p < 0.001) at 1 day and 2% (nonsignificant) after 6 months for Manhattan; 1 versus 2 = 8% (p < 0.05) at 1 day and -9% (nonsignificant) at 6 months in the Bronx
Waterman Ref. 19 1992-94 | Nonrandomized trial, greatest suitability, fair | San Diego County, California; clients - aged 2-4 years; 87% Hispanic; low socioeconomic status | 1 Free walk-in vaccination clinics plus client reminders plus provider education plus multiple education and health promotion strategies plus assessment, referral, and education for WIC clients versus; 2 Usual care | DTP/OPV/MMR (4:3:1 doses, respectively), 1 versus 2 - 12% (statistical significance not found)
Yokley Ref. 20 Time not reported | Group randomized trial (by family), greatest suitability, fair | Akron, Ohio; public health clinic; clients - aged <5 years, mean 37 months; 50% female; 64% white | 1 Mailed general client reminder (195 participants) versus; 2 Mailed specific client reminder (190) versus; 3 Mailed specific client reminder plus special off hours clinics (185) versus; 4 Mailed specific client reminder plus parent incentive lottery (183) versus; 5 Comparison group of usual care (191) | Vaccinated with at least 1 antigen after 3 months, 1 versus 5 = 3% change (nonsignificant); 2 versus 5 = 13% (nonsignificant); 3 versus 5 = 16% (significant); 4 versus 5 = 18% (significant)

##### References

Nicholson KG, Wiselka MJ, May A. Influenza vaccination of the elderly: perceptions and policies of general practitioners and outcome of the 1985-86 immunization programme in Trent, UK. Vaccine. 1987;5:302-6. [pmid: 3433918].
Rodewald LE, Szilagyi PG, Humiston SG, et al. Effect of emergency department immunizations on immunization rates and subsequent primary care visits. Arch Pediatr Adolesc Med. 1996;150:1271-6. [pmid: 8953999].
Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
Elster AB, Lamb ME, Tavare J, Ralston CW. Medical and psychosocial impact of comprehensive care on adolescent pregnancy and parenthood. JAMA. 1987;258:1187-92. [pmid: 3626002].
Hutchison BG, Shannon HS. Effect of repeated annual reminder letters on influenza immunization among elderly patients. J Fam Pract. 1991;33:187-9. [pmid: 1890400].
Frank JW, Henderson M, McMurray L. Influenza vaccination in the elderly: 1. determinants of acceptance. CMAJ. 1985;132:371-5. [pmid: 3971253].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Lukasik MH, Pratt G. Telephone: an overlooked technology for prevention in family medicine. Canad Fam Physician. 1987;33:1997-2001.
Macdonald H, Roder D. Planning, implementation and evaluation of an immunization promotion campaign in South Australia. Hygiene. 1985;4:13-7.
Margolis KL, Nichol KL, Wuorenma J, Von Sternberg TL. Exporting a successful influenza vaccination program from a teaching hospital to a community outpatient setting. J Am Geriatr Soc. 1992;40:1021-3. [pmid: 1401675].
Moran WP, Nelson K, Wofford JL, Velez R. Computer-generated mailed reminders for influenza immunization: a clinical trial. J Gen Intern Med. 1992;7:535-7. [pmid: 1403212].
Nichol KL, Korn JE, Margolis KL, Poland GA, Petzel RA, Lofgren RP. Achieving the national health objective for influenza immunization: success of an institution-wide vaccination program. Am J Med. 1990;89:156-60. [pmid: 2382664].
Nichol KL. Long-term success with the national health objective for influenza vaccination: an institution-wide model. J Gen Intern Med. 1992;7:595-600. [pmid: 1453242].
Nichol KL. Improving influenza vaccination rates for high-risk inpatients. Am J Med. 1991;91:584-8. [pmid: 1750427].
Pierce C, Goldstein M, Suozzi K, Gallaher M, Dietz V, Stevenson J. Impact of the standards for pediatric immunization practices on vaccination coverage levels. JAMA. 1996;276:626-30. [pmid: 8773635].
Szilagyi PG, Rodewald LE, Humiston SG, et al. Effect of 2 urban emergency department immunization programs on childhood immunization rates. Arch Pediatr Adolesc Med. 1997;151:999-1006. [pmid: 9343010].
Waterman SH, Hill LL, Robyn B, et al. Model immunization demonstration for preschoolers in an inner-city barrio, San Diego, California, 1992-94. Am J Prev Med. 1996;12:8-13. [pmid: 8874698].
Yokley JM, Glenwick DS. Increasing the immunization of preschool children: an evaluation of applied community interventions. J Appl Behav Anal. 1984;17:313-25. [pmid: 6439714].

#### Table B-10 Vaccination Programs in WIC Settings Recommended

Table B-10 Vaccination Programs in WIC Settings Recommended

Table B-10 Vaccination Programs in WIC Settings Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Vaccination Programs in WIC Settings Only
Birkhead Ref. 1 1991 | Group randomized trial, greatest suitability, fair | New York City; WIC sites; clients - aged 12-59 months, median age 14 months; urban; 56% Hispanic, 39% black, low socioeconomic status | 1 Assessment of immunization status, education, and referral to provider plus voucher restriction (178 participants) versus; 2 Assessment and referral plus escort to pediatric clinic (377) versus; 3 Comparison group of assessment and referral (281) | MMR, 1 versus 3 = 4% change (p < 0.01); 2 versus 3 = 4% (p < 0.01) after 6 months; 86% of children vaccinated at start of study
Effects of Vaccination Programs in WIC Settings Combined with Other Interventions
Golden Ref. 2 1993-95 | Nonrandomized trial, greatest suitability, fair | Los Angeles, California; WIC sites; clients - aged <16 months; 93% Hispanic, 6% black; low socioeconomic status; urban | 1 Assessment of immunization status, education, and referral to provider plus on-site free vaccinations versus; 2 Assessment and referral plus voucher restriction versus; 3 Assessment and referral plus on-site free vaccinations plus voucher restriction versus; 4 Assessment and referral versus; 5 Comparison group of usual care (Total study population, 2,457 participants pre) | DTP/OPV/MMR (4:3:1 doses, respectively) coverage at 16 months, 1-4 combined versus 5 = 9% change (p < 0.01); in general, no major differences between various intervention combinations
Hutchins Ref. 3 1991-93 | Group randomized trial, greatest suitability, fair | Chicago, Illinois; WIC sites; clients - aged <5 years; 53%-98% black; 1%-42% Hispanic; urban; low socioeconomic status | 1 Assessment of immunization status and education, plus voucher restriction plus referral to on-site clinic, off-site clinic, or on-site nurse; free vaccinations available to all study participants versus; 2 Comparison group of usual standard of care for WIC and healthcare services (Total, 27,596 children in study; 300 aged 13-35 months evaluated in each group) | DTP/OPV/MMR (4:3:1 doses, respectively) at 24 months, 1 versus 2 = 34% change (p < 0.05)
Waterman Ref. 4 1992-94 | Nonrandomized trial, greatest suitability, fair | San Diego County, California; clients - aged 2-4 years; 87% Hispanic; low socioeconomic status | 1 Free walk-in vaccination clinics plus client reminders plus provider education plus multiple education and health promotion strategies plus assessment, referral, and education of WIC clients versus; 2 Usual care | DTP/OPV/MMR (4:3:1 doses, respectively), 1 versus 2 = 12% change (statistical significance not provided)

##### References

Birkhead GS, LeBaron CW, Parsons P, et al. Immunization of children enrolled in the Special Supplemental Food Program for Women, Infants, and Children (WIC): the impact of different strategies. JAMA. 1995;274:312-6. [pmid: 7609260].
Golden RE. Evaluation of three immunization interventions among families participating in the Special Supplemental Nutrition Program for Women, Infants, and Children in South Central and South East Los Angeles [dissertation]. Los Angeles, CA: University of California 1997.
Hutchins SS, Rosenthal J, Eason P, et al. Effectiveness and cost-effectiveness of linking the special supplemental program for women, infants and children (WIC) and immunization activities, 1997. American Journal of Public Health Policy 1999; 20(4). In press.
Waterman SH, Hill LL, Robyn B, et al. Model immunization demonstration for preschoolers in an inner-city barrio, San Diego, California, 1992-94. Am J Prev Med. 1996;12:8-13. [pmid: 8874698].

#### Table B-11 Home Visits Recommended

Table B-11 Home Visits Recommended

Table B-11 Home Visits Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Home Visits Only
Black Ref. 1 1990-92 | Randomized trial, greatest suitability, fair | Ontario, Canada; clients - >65 years; "public health patients;" 66% with >1 chronic health problems | 1 Home visit by public health nurse promoting influenza vaccination and identifying strategies to overcome barriers versus; 2 Comparison group with safety education, (Study group total, 359 participants) | Influenza, 1 versus 2 = -1% change (nonsignificant); 42% of intervention group reported talking with nurse regarding influenza versus 18% of control group
Nicholson Ref. 2 1984 | Cross-sectional study, least-suitable, fair | Trent, United Kingdom; general practitioners; clients - aged >65 years; otherwise, not well-described | 1 Practice policies including any of following: home-bound clients to be vaccinated at home, client reminders, or special vaccination clinics versus; 2 Lack of policies (Study group total, 127 general practitioners surveyed) | Influenza, 1 versus 2 = 10% change (p < 0.05) for home vaccination; influenza, 1 versus 2 = 7% change (p < 0.05) for regular or special immunization clinics
Effects of Home Visits Only and in Combination with Other Interventions
Bond Ref. 3 1996 | Randomized trial, greatest suitability, fair | Australia; community wide; clients - aged 9 or 16 months identified from Australian childhood immunization registry | 1 Letter, telephone, and home contact including administration of vaccination versus; 2 Usual care (Total study population 2,194; 204 and 202 not-up-to-date randomized to intervention and control) | 4 DTP/OPV/Hib at 9 months or 1 MMR at 16 months, 1 versus 2 = 1%
Browngoehl Ref. 4 Kennedy Ref. 5 1992-93 | Retrospective cohort study; moderate suitability; fair | Philadelphia, Pennsylvania; Medicaid managed care group; clients - aged 30-35 months (control group) and 18-24 months (study group), low socioeconomic status | 1 Tracking and reminders plus provider education and incentives plus parent education and incentives plus transportation assistance plus home visits (1,254 participants) versus; 2 Control group of older children (1,257) | 4 DTP/3 OPV/1 MMR at 35 months, 1 versus 2 = 7% change (p < 0.05); 4 DTP/3 OPV/1 MMR/1 Hib at 35 months, 1 versus 2 = 2% change (nonsignificant) Higher coverage in children who received home visits (significance not given)
Rodewald Ref. 6 1994-95 | Randomized trial, greatest suitability, intervention 1 good, intervention 2 fair | Rochester, New York; homes and provider offices, rural health center, hospital-based clinics; clients - aged birth-12 months; urban/rural; 36%-39% black; 6%-10% Hispanic; low/middle socioeconomic status | 1 Lay community services provider-made phone, mail, or home contact (630 participants) versus; 2 Provider education plus feedback plus reminders (744) versus; 3 Both 1 and 2 (648) versus; 4 Usual care (719) Only 12% of group 1 received >1 home visits; only 16% of group 2 received provider reminder | DTP/OPV/MMR/Hib (4:3:1:4 doses, respectively), 1 versus 4 = 20% change (p < 0.001); 2 versus 4 = 1% (p = 0.54); no interaction between 1 and 2; other health outcomes (health visits and anemia and lead screenings) significantly increased in group 1 but not group 2
Rosenberg Ref. 7 1992-93 | Before/after study, least-suitable, fair | New York City; public health clinics, homes, streets; clients - aged <5 years; 54% aged <2 years; urban; 40% Hispanic, 40% black; low socioeconomic status | 1 Local community-based organization performed outreach (e.g., making informal presentations where people congregate or making door-to-door visits) plus disseminated information plus screened vaccination history plus provided vaccination appointments plus reminders/follow-up (2,676 participants) versus; 2 Prior usual care | Evaluation subsample found DTP/OPV/MMR coverage in 1 versus 2 = 49% change (p < 0.05)
Wood Ref. 8 1994 | Randomized trial, greatest suitability, good | Los Angeles, California (10 ZIP codes); homes and clinics; clients - aged <15 months; 90% urban; 100% black, low socioeconomic status | 1 Case management with home visits and telephone contact prior to age 6 weeks and before each vaccination appointment, plus health passport versus; 2 Health passport only (Study group total, 419 participants) | DTP/OPV/Hib (3:2:3 doses, respectively) at 12 months, 1 versus 2 = 13% change (p = 0.01)

##### References

Black ME, Ploeg J, Walter SD, Hutchinson BG, Scott EAF, Chambers LW. Impact of a public health nurse intervention on influenza vaccine acceptance. Am J Public Health. 1993;83:1751-3. [pmid: 8259810].
Nicholson KG, Wiselka MJ, May A. Influenza vaccination of the elderly: perceptions and policies of general practitioners and outcome of the 1985-86 immunization programme in Trent, UK. Vaccine. 1987;5:302-6. [pmid: 3433918].
Bond LM, Nolan TM, Lester RA. Home vaccination for children behind in their immunisation schedule: a randomised controlled trial. Med J Aust. 1998;168:487-90. [pmid: 9631672].
Browngoehl K, Kennedy K, Krotki K, Mainzer H. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1). [pmid: 9096172].
Kennedy KM, Browngoehl K. "High tech," "soft-touch" immunization program for members of a Medicaid managed care organization. HMO Practice. 1994;8:115-21. [pmid: 10157227].
Rodewald LE, Szilagyi PG, Humiston SG, Barth R, Kraus R, Raubertas RF. Randomized study of tracking with outreach and provider prompting to improve immunization coverage and primary care. Pediatrics. 1999;103:31-8. [pmid: 9917436].
Rosenberg Z, Findley S, McPhillips S, Penachio M , Silver P. Community-based strategies for immunizing the "hard-to-reach" child: the New York State immunization and primary health care initiative. Am J Prev Med. 1995;11 (suppl 1):14-20. [pmid: 7669356].
Wood D, Halfon N, Donald-Sherbourne C, et al. Increasing immunization rates among inner-city, African American children: a randomized trial of case management. JAMA. 1998;279:29-34. [pmid: 9424040].

#### Table B-12 Vaccination Programs In Schools Insufficient Evidence

Table B-12 Vaccination Programs In Schools Insufficient Evidence

Table B-12 Vaccination Programs In Schools Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Unti Ref. 1 1992-95 | Multiple designs; least-suitable, fair | San Francisco, California; schools; seventh grade students | 1 Teacher orientation plus classroom lessons plus school assembly plus client education materials plus student vaccination during school hours plus peer and individual incentives (4,928 students) | Hepatitis B (3 doses), coverage post 66%; cannot calculate change because no comparison; 71% of target population consented; 93% of those who consented received 3 doses hepatitis B vaccine; knowledge regarding vaccination increased significantly; peer incentives increased return of consent forms

##### References

Unti LM, Coyle KK, Woodruff BA, Boyer-Chuanroong L. Incentives and motivators in school-based hepatitis B vaccination programs. J Sch Health. 1997;67:265-8. [pmid: 9358379].

#### Table B-13 Vaccination Programs in Child Care Centers Insufficient Evidence

On the basis of the rules of evidence for the Guide to Community Preventive Services, no studies meet the requirements for inclusion in this review.

#### Table B-14 Provider Reminder/Recall Strongly Recommended

Table B-14 Provider Reminder/Recall Strongly Recommended

Table B-14 Provider Reminder/Recall Strongly Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Provider Reminder/Recall Only
Chambers Ref. 1 1987 | Group randomized trial (by physician); greatest suitability, fair | Philadelphia, Pennsylvania; Thomas Jefferson University Family Practice Center; providers - family medicine residents and faculty; clients - adults, 68% aged >65 years; urban; 74% female; 56% black; low socioeconomic status | 1 Physician reminders for all clients versus; 2 Physician reminders for half of all eligible clients versus; 3 Comparison group of never reminded (Total 30 physicians, 635 clients) | Influenza, 1 versus 3 = 21% change (statistical significance not provided)
Cheney Ref. 2 1982-83 | Group randomized trial, greatest suitability, fair | San Diego, California; University of California at San Diego internal medicine house staff training program; providers - residents; clients - adults, 55% aged >60 years; urban; 66% female | 1 Health maintenance checklists incorporated into medical record versus; 2 Comparison group of usual care (Total study group 75 providers; 200 charts audited) | Influenza, 1 versus 2 = 30% change (p < 0.01); pneumococcal, 1 versus 2 = 16% (p < 0.02); Td, 1 versus 2 = 6% (p < 0.05); performance in 9 preventive services, 1 versus 2 = 0.13 (p < 0.002)
Cohen Ref. 3 1980 | Group randomized trial, greatest suitability, fair | Cleveland, Ohio; clinic/hospital; clients - adults, otherwise, target population not well-described | 1 Physician reminders (checklists) on charts plus physician education versus; 2 Comparison group of usual care (Numbers of clients not described) | Influenza, 1 versus 2 = 32% change (p < 0.001); pneumococcal, 1 versus 2 = 37% (p < 0.001); physician attitudes but not knowledge increased posttest (p < 0.05)
Crouse Ref. 4 1992 | Prospective cohort study, greatest suitability, fair | Northern Minnesota; community hospitals; clients - inpatients; adults; otherwise, not well-described | 1 Standing orders versus; 2 Physician reminders in charts versus; 3 Comparison group of physician education (Total, 2 hospitals in each group; client numbers not given) | Influenza, 2 versus 3 = 7% change (nonsignificant); 1 versus 2 = 23% (p < 0.002); 1 versus 3 = 30% (significance not provided)
Gelfman Ref. 5 1983-84 | Time-series study, moderate suitability, fair | Richmond, Virginia; internal medicine training program, clients - adults; urban; otherwise, not well-described | 1 Physician reminders on chart for influenza and pneumococcal versus; 2 Prior usual care versus; 3 Postintervention (158 charts evaluated for influenza and 300 for pneumococcal) | Influenza, 1 versus 2 = 72% change (p < 0.001); pneumococcal, 1 versus 2 = 61%; (p < 0.001); pneumococcal 2 versus 3 = -1% (p > 0.5)
Hahn Ref. 6 1983-84 | Retrospective cohort study, moderate suitability, fair | Midsized midwestern city, provider - family physician in multispecialty group practice; clients - adults; urban; 43%-48% female; predominately white; middle socioeconomic status | 1 Health maintenance flow sheet on chart versus; 2 Comparison group of usual care (Total, 1,862 clients seen during study period; random sample of 250 charts reviewed) | Td, 1 versus 2 = 55% change (p < 0.001); significant increases occurred in most other preventive measures
Harris Ref. 7 Davidson Ref. 8 1979-84 | Time-series study, moderate suitability, fair | North Carolina; university-based general medicine clinic; providers - internal medicine residents and faculty; clients - aged >50 years, mean 64-65 years; 100% female; 50%-60% nonwhite | 1 Nurse-initiated health maintenance checklist and computer-generated reminders on chart (150) versus; 2 Prior usual care (150) | Influenza, 1 versus 2 = 47% (p < 0.001, analysis of variance); pneumococcal, 1 versus 2 = 8% (nonsignificant)
Hutchison Ref. 9 1985-86 | Nonrandomized trial, greatest suitability, fair | Hamilton-Burlington, Canada; family practice; health service organization; providers - "experienced family physicians" and nurse practitioners; clients - aged >65 years; urban; 27%-33% with high-risk conditions | 1 Provider reminder message on computer encounter form on chart (593 participants) versus; 2 Comparison group of usual care (618) | Influenza, 1 versus 2 = 16% change; significant increase in intervention group but not in comparison; no difference between clients at high risk versus those not at high risk
Klein Ref. 10 1980-81 | Randomized trial, greatest suitability, fair | Bronx, New York; North Central Bronx Hospital; clients - urban; inpatients; adults; mean age 61 years; 64% female; 27%-33% with high-risk conditions | 1 Provider reminders on chart versus; 2 Comparison group of usual care (600 total participants) | Pneumococcal, 1 versus 2 = 8% change (p < 0.05); 18% change year 2 (p < 0.001)
McDonald Ref. 11 1978-80 | Group randomized trial (by practice team), greatest suitability, fair | Indianapolis, Indiana; academic general internal medicine training program; providers: staff and resident physicians, nurses and nurse practitioners; clients - adults; 60% aged >50 years; urban; 65% female; 65% black | 1 Computerized reminders on chart versus; 2 Comparison group of usual care (Total 12,467 client visits) | Influenza, 1 versus 2 = 25% change (p < 0.0001); pneumococcal, 1 versus 2 = 40% (p < 0.0001); significant improvements in all 13 other preventive services
McDowell Ref. 12 Rosser Ref. 13 1983-85 | Group randomized trial (by family), greatest suitability, fair | Ottawa, Canada; University of Ottawa Family Medicine Center at Civic Hospital; providers - staff and resident physicians, nurses; clients - aged >65 years | 1 Computer-generated provider reminder (218 participants) versus; 2 Client reminder by telephone (226) versus; 3 Client reminder by letter (231) versus; 4 Comparison group of randomized controls (230) | Influenza, 1 versus 4 = 13% change (p < 0.005); 2 versus 4 = 26% (p < 0.005); 3 versus 4 = 26% (p < 0.005) ; Td, 1 versus 4 = 20% (CI = 17%-22%); 2 versus 4 = 21% (CI = 18%-24%); 3 versus 4 = 27% (CI = 25%-31%)
Rodewald Ref. 14 1990-91 | Randomized trial, greatest suitability, fair | Rochester, New York; emergency department and primary-care sites; clients - aged 6-36 months; urban; 55%-59% male; 43%-48% black; low socioeconomic status | 1 Provider reminders by mail (610 participants) versus; 2 Immunization offered on-site at emergency department (611) versus; 3 Comparison group of usual care (614) All children enrolled through emergency department | Up-to-date with DTP/OPV/MMR/Hib, 1 versus 3 = no significant difference; 2 versus 3 = 8% change (p = 0.002) at 1 month, but 2 versus 3 = 3% (p = 0.2) at 12 months
Shreiner Ref. 15 1980-88 | Other designs with concurrent comparison groups, greatest suitability, fair | Galveston, Texas; general internal medicine house staff clinics of University of Texas; clients - adults, mean ages 56-57 years; urban; 71%-73% female; 49%-54% black; 35%-39% Hispanic | 1 Provider reminders on chart (baseline 900 participants; during 180, post 180) versus; 2 Concurrent comparison group of usual care (baseline 168; during 168, post 168) | Pneumococcal, 1 versus 2 = 11% change; group 1 coverage during intervention significantly differs from coverage pre and post
Szilagyi Ref. 16 1991-93 | Randomized trial, greatest suitability, fair | Rochester, New York; pediatric clinic at teaching hospital and neighborhood health center; providers - attending pediatricians, residents, nurses, nurse practitioners; clients - children, mean ages 7-13 months; urban; 52%-53% male; 70% black, low socioeconomic status | 1 Provider reminders on chart versus; 2 Comparison group of usual care (Total population 1,988 participants before randomization). Both groups had policy change encouraging simultaneous administration of vaccinations, and neighborhood health center changed policy to allow any adult to provide consent | Up-to-date with DTP/OPV/MMR/Hib, 1 versus 2 = 3% change at clinic (p = 0.3) and -2% at neighborhood health center (p = 0.5); significant changes occurred if analyzed subset for whom reminder card actually used
Tape Ref. 17 1986-87 | Nonrandomized trial (by physician clinic day), greatest suitability, fair | Omaha, Nebraska; general internal medicine at University of Nebraska Hospital; providers - faculty and residents; clients - adults; urban; otherwise, target population not described | 1 Computerized provider reminders at visit versus; 2 Healthcare maintenance flow sheet in chart (Total population, 892 participants before randomization) | Performance of Hemoccult^®^, proctoscopy, influenza vaccination increased significantly; performance of mammogram, Td vaccination increased (nonsignificant); performance of Papanicolaou (Pap) smears did not increase
Weingarten Ref. 18 1985-87 | Nonrandomized trial, greatest suitability, fair | Israel; community health center; provider - one family practitioner; clients - adults; low socioeconomic status | 1 Protocol for adult health maintenance displayed on desktop computer (112 participants) versus; 2 Comparison group of usual care (93) | Td, 1 versus 2 = 26% change (p < 0.001); significant increases in most other preventive care
Effects of Provider Reminder/Recall in Combination with Other Interventions
Barton Ref. 19 1983-87 | Time-series study, moderate suitability, fair | Boston, Massachusetts; clinic/provider's offices; clients - aged >65 years; urban | 1 Client reminders plus client education plus provider reminders versus; 2 Same plus feedback to individual physicians versus; 3 Previous usual care (Total study population, 647 participants) | Influenza, 1 versus 3 = 18% change; 2 versus 3 = 36% (statistical significance not reported)
Frame Ref. 20 1991-92 | Group randomized trial, greatest suitability, fair | Dansville, New York; family practice offices; providers - family physicians and physician's assistants; clients - aged >21 years; rural; low/middle socioeconomic status | 1 Computer-based telephone client reminders plus provider reminders on chart (829 participants) versus; 2 Comparison group of client reminders triggered by physician request (836) | Td, 1 versus 2 = 21% change (CI = 16%-26%); change for all preventive care was 11%
Harper Ref. 21 1993-94 | Nonrandomized trial, greatest suitability, fair | St. Paul, Minnesota; family practice residency clinic (intervention); community health center (control); clients - children aged 24-35 months; urban; 54%-56% male; 86%-93% white; low socioeconomic status | 1 Physician reminder on chart plus client education plus feedback regarding performance (280 participants) versus; 2 Comparison group of usual care (239) | DTP/OPV/MMR (4:3:1 doses, respectively), at age 24-35 months, 1 versus 2 = 12% change (p < 0.02)
Harper Ref. 22 1990-91 | Nonrandomized trial, greatest suitability, fair | St. Paul, Minnesota; family practice residency clinic (intervention); community health center (control); clients - aged 11-18 years; urban; 55%-59% female; 87%-90% white; low socioeconomic status | 1 Provider reminders on chart after assessment by front desk plus feedback to front desk (733 participants pre, 737 post) versus; 2 Comparison group of usual care (599 pre, 812 post) | Net percentage change of client visits where client was up-to-date for MMR was 24%
Karuza Ref. 23 1990-92 Calkins Ref. 24 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart or client reminders or waiting room posters or provider education or standing orders or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Korn Ref. 25 1984-85 | Time-series study, moderate suitability, fair | Minneapolis, St. Paul; internal medicine resident's clinic at a hospital; clients - adults; mean age 52-56 years; urban/suburban; 35%-42% male | 1 Instructional seminars plus biweekly provider feedback plus provider reminders (202 participants) versus; 2 Prior usual care (199) | Influenza, 1 versus 2 = -3% change (nonsignificant); pneumococcal, 1 versus 2 = 15% (p < 0.01)
Lukasik Ref. 26 1985 | Nonrandomized trial, greatest suitability, fair | London, Ontario; Victoria Family Medicine Center; providers - staff physician, resident physicians, registered nurse and registered nursing assistant; clients - aged >65 years; otherwise, not well-described | 1 Provider reminders on chart plus client education plus waiting room poster plus client reminders plus increased access (120 participants) versus; 2 Provider reminders on chart plus client education plus poster (123); 3 Previous usual care | Influenza, 1 versus 2 = 22% change (p = 0.002); 1 versus 3 = 44%; 2 versus 3 = 22%
Paunio Ref. 27 1982-86 | Time-series study, moderate suitability, fair | Finland; communitywide; target population - aged birth-11 years | 1 Registry plus mass-media reporting of local data regarding vaccination coverage plus provider reminders plus parent reminders versus; 2 Usual care before registry | MMR, 1 versus 2 = 8% change (no significance testing) Fitted weekly time-series models of number of MMR delivered 1 versus 2, no effect on number of vaccinations administered to children aged 14-18 months; mass-media might have increased vaccinations administered to children aged 6 years; all three interventions increased numbers of children aged 6 years who received first MMR
Rodewald Ref. 28 1994-95 | Randomized trial, greatest suitability, intervention 1 good, intervention 2 fair | Rochester, New York; homes and provider offices, rural health center, hospital-based clinics; clients - aged birth-12 months; urban/rural; 36%-39% black; 6%-10% Hispanic; low/middle socioeconomic status | 1 Lay community services provider made phone, mail, or home contact (630 participants) versus; 2 Provider education plus feedback plus reminders (744) versus; 3 Both 1 and 2 (648) versus; 4 Usual care (719) Only 12% of group 1 received 1 home visits; only 16% of group 2 received provider reminder | DTP/OPV/MMR/Hib (4:3:1:4 doses, respectively), 1 versus 4 = 20% change (p < 0.001); 2 versus 4 = 1% (p = 0.54); no interaction between 1 and 2; other health outcomes (health visits and anemia and lead screenings) significantly increased in group 1 but not group 2
Effects of Provider Reminder/Recall Only and in Combination with Other Interventions
Becker Ref. 29 1986-87 | Randomized trial, greatest suitability, fair | Charlottesville, Virginia; University of Virginia medicine clinic; providers - residents; clients - aged 40-60 years, mean 51-52; 64%-72% female; 50%-60% black; low socioeconomic status | 1 Physician and client reminders (168 participants) versus; 2 Physician reminders (203) versus; 3 Comparison group (192) | Influenza, pneumococcal, and Td, 2 versus 3 = 9%, 2%, and 6% change, respectively; 1 versus 3 = 16%, 1%, 8%, respectively (analysis of variance for groups 1, 2, and 3 only significant for Td)
Ornstein Ref. 30 1988-89 | Group randomized trial (by practice group), greatest suitability, fair | South Carolina; family medicine center at University of South Carolina; providers - faculty, residents, and fellows in family medicine; clients - aged >18 years, mean age 40 years; urban; 61% female; 61% black; low socioeconomic status | 1 Computerized physician reminders on chart (1,988 participants) versus; 2 Client reminders (1,925) versus; 3 Physician and client reminders (1,908) versus; 4 Comparison group of usual care (1,576) | Td, 1 versus 4 = 6.7% change; 2 versus 4 = 5.7%; 3 versus 4 = 8.2%; significant improvements in 3 of 4 other preventive services
Tierney Ref. 31 1983-84 | Randomized trial, greatest suitability, fair | Indianapolis; university-based clinic; providers - residents; clients - adults; urban; otherwise, not well-described | 1 Provider reminders on chart versus; 2 Monthly feedback versus; 3 Both; 4 Comparison group received reminders regarding other preventive care (135 resident physicians; total, 1,750 clients) | Pneumococcal, 1 versus 4 = 30% change; 2 versus 4 = 14%; 3 versus 4 = 28% (no statistical tests reported); pattern for other preventive care similar
Turner Ref. 32 1984 | Nonrandomized trial, greatest suitability, fair | Philadelphia, Pennsylvania; internal medicine resident physician clinic; providers - junior and senior resident physicians; clients - adults, mean age 60-62 years; urban; 69%-78% female; low socioeconomic status | 1 Computerized provider reminders (103 charts audited) versus; 2 Written client educational materials plus questionnaire reviewed by provider (86 charts audited) versus; 3 Both (64 charts audited) versus; 4 Prior usual care for all groups (Total 39 resident physicians) | Td was <10% for all groups pre and post and had not improved 1 year later; other preventive care significantly improved in 3 versus 4; physician knowledge by questionnaire increased (nonsignificant)

##### References

Chambers CV, Balaban DJ, Carlson BL, Grasberger DM. Effect of microcomputer-generated reminders on influenza vaccination rates in a university-based family practice center. J Am Board Fam Pract. 1991;4:19-26. [pmid: 1996510].
Cheney C, Ramsdell JW. Effect of medical records' checklists on implementation of periodic health measures. Am J Med. 1987;83:129-36. [pmid: 3605164].
Cohen DI, Littenberg B, Wetzel C, Neuhauser D. Improving physician compliance with preventive medicine guidelines. Med Care. 1982;20:1040-5. [pmid: 7132464].
Crouse BJ, Nichol K, Peterson DC, Grimm MB. Hospital-based strategies for improving influenza vaccination rates. J Fam Pract. 1994;38:258-61. [pmid: 8126406].
Gelfman DM, Witherspoon JM, Buchsbaum DG, Centor RM. Short-term results of an immunization compliance program. Virginia Medical. 1986;113:532-4. [pmid: 3776344].
Hahn DL, Berger MG. Implementation of a systematic health maintenance protocol in a private practice. J Fam Pract. 1990;31:492-504. [pmid: 2230674].
Harris RP, O'Malley MS, Fletcher SW, Knight BP. Prompting physicians for preventive procedures: a five-year study of manual and computer reminders. Am J Prev Med. 1990;6:145-52. [pmid: 2397138].
Davidson RA, Fletcher SW, Retchin S, Duh S. Nurse-initiated reminder system for the periodic health examination: implementation and evaluation. Arch Intern Med. 1984;144:2167-70. [pmid: 6333855].
Hutchison BG. Effect of computer-generated nurse/physician reminders on influenza immunization among seniors. Fam Med. 1989;21:433-7. [pmid: 2612799].
Klein RS, Adachi N. Pneumococcal vaccine in the hospital: improved use and implications for high-risk patients. Arch Intern Med. 1983;143:1878-81. [pmid: 6354122].
McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record: a two-year randomized trial. Ann Intern Med. 1984;100:130-8. [pmid: 6691639].
McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135:991-7. [pmid: 3093045].
Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 1991;145:807-14. [pmid: 1913409].
Rodewald LE, Szilagyi PG, Humiston SG, et al. Effect of emergency department immunizations on immunization rates and subsequent primary care visits. Arch Pediatr Adolesc Med. 1996;150:1271-6. [pmid: 8953999].
Shreiner DT, Petrusa ER, Rettie CS, Kluge RM. Improving compliance with preventive medicine procedures in a house staff training program. South Med J. 1988;81:1553-7. [pmid: 3201302].
Szilagyi PG, Rodewald LE, Humiston SG, et al. Reducing missed opportunities for immunizations: easier said than done. Arch Pediatr Adolesc Med. 1996;150:1193-200. [pmid: 8904862].
Tape TG, Givner N, Wigton RS. Process in ambulatory care: a controlled clinical trial of computerized records. Symposium on Computer Applications in Medical Care 1988; 749-52.
Weingarten MA, Bazel D, Shannon HS. Computerized protocol for preventive medicine: a controlled self-audit in family practice. Fam Pract. 1989;6:120-4. [pmid: 2744295].
Barton MB, Schoenbaum SC. Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health. 1990;80:534-6. [pmid: 2327527].
Frame PS, Zimmer JG, Werth PL, Jackson Hall W, Eberly SW. Computer-based vs manual health maintenance tracking: a controlled trial. Arch Fam Med. 1994;3:581-8. [pmid: 7921293].
Harper PG, Madlon-Kay DJ, Luxenberg MG, Tempest R. Clinic system to improve preschool vaccinations in a low socioeconomic status population. Arch Pediatr Adolesc Med. 1997;151:1220-3. [pmid: 9412597].
Harper PG, Murray DM. Organizational strategy to improve adolescent measles-mumps-rubella vaccination in a low socioeconomic population: a method to reduce missed opportunities. Arch Fam Med. 1994;3:257-62. [pmid: 8180716].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Korn JE, Schlossberg LA, Rich EC. Improved preventive care following an intervention during an ambulatory care rotation: carryover to a second setting. J Gen Intern Med. 1988;3:156-60. [pmid: 3357072].
Lukasik MH, Pratt G. Telephone: an overlooked technology for prevention in family medicine. Canad Fam Physician. 1987;33:1997-2001.
Paunio M, Virtanen M, Peltola H, et al. Increase of vaccination coverage by mass media and individual approach: intensified measles, mumps, and rubella prevention program in Finland. Am J Epidemiol. 1991;133:1152-60. [pmid: 2035518].
Rodewald LE, Szilagyi PG, Humiston SG, Barth R, Kraus R, Raubertas RF. Randomized study of tracking with outreach and provider prompting to improve immunization coverage and primary care. Pediatrics. 1999;103:31-8. [pmid: 9917436].
Becker DM, Gomez EB, Kaiser DL, Yoshihasi A, Hodge RH. Improving prevention care at a medical clinic: how can the patient help?. Am J Prev Med. 1989;5:353-9. [pmid: 2597431].
Ornstein SM, Garr DR, Jenkins RG, Rust PF, Arnon A. Computer-generated physician and patient reminders: tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32:82-90. [pmid: 1985140].
Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care: effects on physician compliance. Medical Care. 1986;24:659-66. [pmid: 3736141].
Turner BJ, Day SC, Borenstein B. Controlled trial to improve delivery of preventive care: physician or patient reminders. J Gen Intern Med. 1989;4:403-9. [pmid: 2677271].

#### Table B-15 Assessment and Feedback for Vaccination Providers Strongly Recommended

Table B-15 Assessment and Feedback for Vaccination Providers Strongly Recommended

Table B-15 Assessment and Feedback for Vaccination Providers Strongly Recommended

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Giving Feedback to Vaccination Providers Only
Carey Ref. 1 1987 and 1989 | Before/after study, least-suitable, fair | North Carolina; state supported clinics, community health centers, National Health Service Corps sites; rural; clients - adults, low socioeconomic status | 1 Chart audits and feedback versus; 2 Prior usual care (37 practices, 40 physicians) | Influenza, 1 versus 2 = -11% change; other prevention practices demonstrated improvements
Kern Ref. 2 1981-87 | Before/after study, least-suitable, fair | Baltimore, Maryland; university teaching hospital; providers: internal medicine residents; clients - adults, 56% female; "working class" | 1 Chart audits and feedback versus; 2 Prior usual care (139 medical residents) | Td, pneumococcal, influenza, 1 versus 2 = 8%, 18%, 32%, respectively (significance not reported)
Kouides Ref. 3 1990-91 | Nonrandomized trial, greatest suitability, fair | Monroe County, New York; private physician offices; providers - predominantly internal medicine; clients - aged >65 years; urban/suburban; middle/high socioeconomic status | 1 Provider feedback plus provider incentives versus; 2 Provider feedback (Total 135 physician practices) | Influenza, 1 versus 2 = 17% change (p < 0.001) (9% adjusted measure); rates in practices using client reminders were lower than in practices not using reminders (i.e., postcards), 54%
LeBaron Ref. 4 Dini Ref. 5 1988-94 | Time-series study, moderate suitability, fair | Georgia; public immunization clinics; clients - aged 21-23 months; mixed urbanistically | 1 Annual provider audit and feedback to clinic staff (136,004 participants) versus; 2 Prior usual care Clinics implemented variety of interventions in response to feedback; certain clinics used award plaques for good performance | DTP/OPV/MMR (4:3:1 doses, respectively), 1 versus 2 = 41% change (statistical significance not reported)
Lynch Ref. 6 1991-92 | Cross-sectional study, least-suitable, fair | Scotland; general practice clinics; clients - aged birth-24 months, otherwise, population not well-described | 1 Provider feedback plus incentives for "high" target coverage versus; 2 Provider feedback plus incentives for "low" target coverage versus; 3 Provider feedback plus no incentives for "below" target coverage (Total 208 practices) | Up-to-date with DTP/OPV/MMR; previous bonuses had significant effects on coverage levels by ordinary least squares regression and on likelihood of achieving high targets by logistic regression
Effects of Giving Feedback to Vaccination Providers in Combination with Other Interventions
Barton Ref. 7 1983-87 | Time-series study, moderate suitability, fair | Boston, Massachusetts; clinic/provider's offices; clients - aged >65 years; urban | 1 Client reminders plus client education plus provider reminders versus; 2 Same plus feedback to individual physicians versus; 3 Previous usual care (Total study population, 647 participants) | Influenza, 1 versus 3 = 18% change; 2 versus 3 = 36%; (statistical significance not reported)
Chodroff Ref. 8 1986-89 | Before/after study, least-suitable, fair | York, Pennsylvania; Internal Medicine outpatient clinics at York Hospital; providers - internal medicine residents; clients - mean age 49-51 years, 55%-58% male | 1 Provider feedback plus provider reminders plus provider education versus; 2 Prior usual care (Random sample 400 charts pre; all 1,612 clients post) | Td, pneumococcal, influenza, 1 versus 2 = 43%, 38%, 49%, changes, respectively (significance not reported)
Harper Ref. 9 1993-94 | Nonrandomized trial, greatest suitability, fair | St Paul, Minnesota; family practice residency clinic (intervention); community health center (control); providers - family medicine residents and staff; clients - children aged 24-35 months, urban, 54%-56% male, 86%-93% white, low socioeconomic status | 1 Physician reminder on chart plus client education plus feedback on performance (280 participants) versus; 2 Comparison group of usual care (239) | DTP/OPV/MMR (4:3:1 series) at age 24 months, 1 versus 2 = 12% change (p < 0.02)
Harper Ref. 10 1990-91 | Nonrandomized trial, greatest suitability, fair | St. Paul, Minnesota; family practice residency clinic (intervention); community health center (control); providers - family medicine residents (intervention) and staff (control); clients - aged 11-18 years; urban; 55%-59% female; 87%-90% white; low socioeconomic status | 1 Provider reminders on chart after assessment by front desk plus feedback to front desk (733 participants pre, 737 post) versus; 2 Comparison group of usual care (599 pre, 812 post) | Net percentage change of client visits where client was up-to-date for MMR was 24%
Karuza Ref. 11 1990-92 Calkins Ref. 12 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart or client reminders or waiting room posters or provider education or standing orders or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Korn Ref. 13 1984-95 | Time-series study, moderate suitability, fair | Minneapolis, St. Paul, Minnesota; internal medicine resident's clinic at a hospital; clients - adults; mean age 52-56 years; urban/suburban; 35%-42% male | 1 Instructional seminars plus biweekly provider feedback plus provider reminders (202 participants) versus; 2 Prior usual care(199) | Influenza, 1 versus 2 = ~3% change (nonsignificant); pneumococcal, 1 versus 2 = 15% (p < 0.01)
Rodewald Ref. 14 1994-95 | Randomized trial, greatest suitability, intervention 1 good, intervention 2 fair | Rochester, New York; homes and provider offices, rural health center, hospital-based clinics; clients - aged birth-12 months; urban/rural; 36%-39% black; 6%-10% Hispanic; low/middle socioeconomic status | 1 Lay community services provider made phone, mail, or home contact (630 participants) versus; 2 Provider education plus feedback plus reminders (744) versus; 3 Both 1 and 2 (648) versus; 4 Usual care (719) Only 12% of group 1 received 1 home visits; only 16% of group 2 received provider reminder | DTP/OPV/MMR/Hib (4:3:1:4 doses, respectively), 1 versus 4 = 20% change (p < 0.001); 2 versus 4 = 1% (p = 0.54); no interaction between 1 and 2; other health outcomes (health visits and anemia and lead screenings) significantly increased in group 1 but not group 2
Effects of Giving Feedback to Vaccination Providers Only and in Combination with Other Interventions
Buffington Ref. 15 1989 | Randomized trial, greatest suitability, fair | Rochester, New York; private physician offices; clients - aged 65 years; urban/suburban; otherwise, not well-described | 1 Provider feedback versus; 2 Provider feedback plus mailed client remainders versus; 3 Comparison group of usual care (Total study population, 10,525 participants) | Influenza, 1 versus 3 = 16% change (p < 0.001); 2 versus 3 = 17% (p < 0.001)
Tierney Ref. 16 1983-84 | Randomized trial, greatest suitability, fair | Indianapolis; university-based clinic; providers - residents; clients - adults; urban; otherwise, not well-described | 1 Provider reminders on chart versus; 2 Monthly feedback versus; 3 Both; 4 Comparison group received reminders regarding other preventive care (135 resident physicians; total, 1,750 clients) | Pneumococcal, 1 versus 4 = 30% change; 2 versus 4 = 14%; 3 versus 4 = 28% (no statistical tests reported); pattern for other preventive care similar

##### References

Carey TS, Levis D, Pickard CG, Bernstein J. Development of a model quality-of-care assessment program for adult preventive care in rural medical practices. Quality Review Bulletin. 1991;17:54-9. [pmid: 2034441].
Mukherji PS, Ryan MP, Howie JGR, Stevenson JSK. Consultation behaviour and the influence of the media. Journal of the Royal College of General Practitioners. 1982;32:242-4. [pmid: 7086758].
Kouides RW, Lewis B, Bennett NM, et al. Performance-based incentive program for influenza immunization in the elderly. Am J Prev Med. 1993;9:250-5. [pmid: 8398226].
LeBaron CW, Chaney M, Baughman AL, et al. Impact of measurement and feedback on vaccination coverage in public clinics, 1988-1994. JAMA. 1997;277:631-5. [pmid: 9039880].
Dini EF, Chaney M, Moolenaar RL, LeBaron CW. Information as intervention: how Georgia used vaccination coverage data to double public sector vaccination coverage in seven years. Journal of Public Health Management Practice. 1996;2:45-9.
Lynch ML. Uptake of childhood immunization and financial incentives to general practitioners. Health Econ. 1994;3:117-25. [pmid: 8044212].
Barton MB, Schoenbaum SC. Improving influenza vaccination performance in an HMO setting: the use of computer-generated reminders and peer comparison feedback. Am J Public Health. 1990;80:534-6. [pmid: 2327527].
Chodroff CH. Cancer screening and immunization quality assurance using a personal computer. Quality Review Bulletin. 1990;16:279-87. [pmid: 2122353].
Harper PG, Madlon-Kay DJ, Luxenberg MG, Tempest R. Clinic system to improve preschool vaccinations in a low socioeconomic status population. Arch Pediatr Adolesc Med. 1997;151:1220-3. [pmid: 9412597].
Harper PG, Murray DM. Organizational strategy to improve adolescent measles-mumps-rubella vaccination in a low socioeconomic population: a method to reduce missed opportunities. Arch Fam Med. 1994;3:257-62. [pmid: 8180716].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Korn JE, Schlossberg LA, Rich EC. Improved preventive care following an intervention during an ambulatory care rotation: carryover to a second setting. J Gen Intern Med. 1988;3:156-60. [pmid: 3357072].
Rodewald LE, Szilagyi PG, Humiston SG, Barth R, Kraus R, Raubertas RF. Randomized study of tracking with outreach and provider prompting to improve immunization coverage and primary care. Pediatrics. 1999;103:31-8. [pmid: 9917436].
Buffington J, Bell KM, LaForce FM. Target-based model for increasing influenza immunizations in private practice. J Gen Intern Med. 1991;6:204-9. [pmid: 2066823].
Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care: effects on physician compliance. Med Care. 1986;24:659-66. [pmid: 3736141].

#### Table B-16 Standing Orders Strongly Recommended for Adults Insufficient Evidence for Children

Table B-16 Standing Orders Strongly Recommended for Adults Insufficient Evidence for Children

Table B-16 Standing Orders Strongly Recommended for Adults Insufficient Evidence for Children

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Standing Orders Only
Christy Ref. 1 1990-91 | Nonrandomized trial, greatest suitability, fair | Rochester, New York; pediatric resident clinic; clients - aged 2-60 months; urban; predominantly low socioeconomic status | 1 Nurse-guided assessment and algorithm plus standing orders (875 participants) versus usual care in 2 and 3; 2 Concurrent controls (1,226) and; 3 Historical controls (713) | DTP (4 doses), 1 versus 2 = -4% change; 1 versus 3 = 4%; MMR, >92% coverage in all groups
Crouse Ref. 2 1991 | Prospective cohort study, greatest suitability, fair | Northern Minnesota; community hospitals; clients - inpatients; adults; otherwise, not described | 1 Standing orders (2 hospitals) versus; 2 Physician reminders (2 hospitals) versus; 3 Comparison group of physician education (2 hospitals) (Numbers of clients not provided) | Influenza, 1 versus 2 = 23% change (p < 0.002); 1 versus 3 = 30% (significance not provided); 2 versus 3 = 7% (nonsignificant)
Hoey Ref. 3 1980 | Nonrandomized trial, greatest suitability, fair | Montreal; teaching hospital-based polyclinic; clients not described | 1 Standing orders (435 participants) versus; 2 Usual practice (348) | Influenza, 1 versus 2 = 33% change (significance not provided)
Klein Ref. 4 1984 | Nonrandomized trial, greatest suitability, fair | Bronx, New York; teaching hospital; clients - median ages, 56-63 years; 57%-59% male | 1 Standing orders (90 participants) versus; 2 Usual practice (97) | Pneumococcal, 1 versus 2 = 69% change (p < 0.001)
Margolis Ref. 5 1986 | Retrospective cohort study, moderate suitability, fair | Minneapolis, Minnesota; general medicine specialty clinic; clients - aged >65 years | 1 Standing orders (97 participants) versus; 2 Concurrent comparison (106) and historical comparison (73) | Influenza, 1 versus 2 = 52% change (p < 0.001); 1 versus 3 = 53% (p < 0.001); outcomes in vaccinations offering, coverage not reported
Morton Ref. 6 Time not reported | Nonrandomized trial, greatest suitability, fair | Location not reported; long-term care facilities; clients not described | 1 Standing orders versus; 2 Usual care (Total 172 clients) | Pneumococcal, 1 versus 2 = 81% (significant)
Effects of Standing Orders in Combination with Other Interventions
Herman Ref. 7 1989-90 | Randomized trial, greatest suitability, good | Cleveland, Ohio; academic clinical organization; clients - >65 years; 67% female, predominantly white | 1 Standing orders/client education/provider education (prevention team) (387 participants) versus; 2 Client/provider education (389) versus; 3 Provider education (426) | Influenza, 1 versus 3 = 13% change; pneumococcal, 19% (significant); 2 versus 3 @@@061@@@ 3% influenza and 2% pneumococcal (nonsignificant)
Karuza Ref. 8 1990-92 Calkins Ref. 9 1991-92 | Group randomized trial, both greatest suitability, good and fair, respectively | Buffalo, New York; private practices; providers - 33% family practice and 67% internal medicine; clients - adults; urban; 80% male | 1 Provider feedback plus one or more of provider reminders on chart or client reminders or waiting room posters or provider education or standing orders or special appointments versus; 2 Comparison group underwent similar process for nonsteroidal drug prescribing (51 physicians) | Influenza, 1 versus 2 = 16% change (p < 0.01); no change in pre/post knowledge or attitudes
Margolis Ref. 10 1989-90 | Nonrandomized trial, greatest suitability, fair | Urban/suburban Minneapolis-St. Paul, Minnesota; staff model health maintenance organization; clients - aged >65 years | 1 Standing orders, client reminder/recall, provider education, expanded access versus; 2 Usual care (Two clinics in each group; outcomes assessed in 150 randomly chosen clients/clinics) | Influenza, intervention clinic 1 versus comparison clinic 1 = -8% change; intervention clinic 2 versus comparison clinic 2 = 20%; post- versus prechange in intervention clinic 2 (significant, p = 0.01); changes in other clinics nonsignificant
Nichol Ref. 11 1987 Nichol Ref. 12 1987-92 | Other designs with concurrent comparison groups, greatest suitability, time-series study, moderate suitability, both fair | Minneapolis, Minnesota, versus other midwestern cities; VA outpatient services; clients - veterans | 1 Standing orders, walk-in "flu-shot" clinics, provider reminders, vaccination stations in busy clinic areas, mailing to all outpatients (378 participants) versus; 2 Usual care at 3 other midwestern academic hospitals (997) | Influenza, 1 versus 2 = 26% change (p < 0.00001); time-series data found that coverage rates continued to increase for 5 years; additional 15% among all clients (p < 0.0001)
Nichol Ref. 13 1990 | Prospective cohort study, greatest suitability, fair | Minneapolis, Minnesota; VA hospital; clients - veterans aged >65 years | 1 Standing orders and vaccination stations among inpatients versus; 2 Standing orders and provider reminders and walk-in "flu-shot" clinics and educational mailings among outpatients | Influenza, prior to intervention, inpatient coverage <25% and outpatient coverage >60%; addition of policy for inpatients brought inpatient coverage to 79%, which did not differ significantly from outpatient levels

##### References

Christy C, McConnochie KM, Zernik N, Brzoza S. Impact of an algorithm-guided nurse intervention on the use of immunization opportunities. Arch Pediatr Adolesc Med. 1997;151:384-91. [pmid: 9111438].
Crouse BJ, Nichol K, Peterson DC, Grimm MB. Hospital-based strategies for improving influenza vaccination rates. J Fam Pract. 1994;38:258-61. [pmid: 8126406].
Hoey JR, McCallum HP, Lepage EM. Expanding the nurse's role to improve preventive service in an outpatient clinic. CMAJ. 1982;127:27-8. [pmid: 7083107].
Klein RS, Adachi N. Effective hospital-based pneumococcal immunization program. Arch Intern Med. 1986;146:327-9. [pmid: 3947193].
Margolis KL, Lofgren RP, Korn JE. Organizational strategies to improve influenza vaccine delivery: a standing order in a general medicine clinic. Arch Intern Med. 1988;148:2205-7. [pmid: 3178378].
Morton MR, Spruill WJ, Cooper JW. Pharmacist impact on pneumococcal vaccination rates in long-term-care facilities. American Journal of Hospital Pharmacy. 1988;45. [pmid: 3126652].
Herman CJ, Speroff T, Cebul RD. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. 1994;42:1154-9. [pmid: 7963201].
Karuza J, Calkins E, Feather J, Hershey CO, Katz L, Majeroni B. Enhancing physician adoption of practice guidelines: dissemination of influenza vaccination guideline using a small-group consensus process. Arch Intern Med. 1995;155:625-32. [pmid: 7887759].
Calkins E, Katz LA, Karuza J, Wagner A. Small group consensus process for changing physician practices: influenza vaccination. HMO Practice. 1995;9:107-10. [pmid: 10151093].
Margolis KL, Nichol KL, Wuorenma J, Von Sternberg TL. Exporting a successful influenza vaccination program from a teaching hospital to a community outpatient setting. J Am Ger Soc. 1992;40:1021-3.
Nichol KL, Korn JE, Margolis KL, Poland GA, Petzel RA, Lofgren RP. Achieving the national health objective for influenza immunization: success of an institution-wide vaccination program. Am J Med. 1990;89:156-60. [pmid: 2382664].
Nichol KL. Long-term success with the national health objective for influenza vaccination: an institution-wide model. J Gen Intern Med. 1992;7:595-600. [pmid: 1453242].
Nichol KL. Improving influenza vaccination rates for high-risk inpatients. Am J Med. 1991;91:584-8. [pmid: 1750427].

#### Table B-17 Provider Education Only Insufficient Evidence

Table B-17 Provider Education Only Insufficient Evidence

Table B-17 Provider Education Only Insufficient Evidence

Author, Reference Number, Study Period | Design, Category, Execution | Study Location, Setting Type, Population Description | Interventions Studied, Comparisons, (Number of Participants) | Outcomes and Effect Measures, Including Percentage Point Change Unless Otherwise Noted (Statistical Significance)
Effects of Provider Education on Vaccination Coverage
Cowan Ref. 1 1985 | Group randomized trial, greatest suitability, fair | Illinois; internal medicine resident clinic, University of Illinois; clients - adults, mean ages 57-60 years | 1 Generic health assessment fact sheet attached to client's chart (62 participants, 16 physicians) versus; 2 Comparison group of usual care (45 participants, 13 physicians) | Pneumococcal, 1 versus 2 = 10% change (nonsignificant); influenza, 1 versus 2 = -1%; no significant difference in physician knowledge or attitudes
Crouse Ref. 2 1991 | Prospective cohort study, greatest suitability, fair | Northern Minnesota; community hospitals; clients - inpatients; adults; otherwise, not described | 1 Standing orders (2 hospitals) versus; 2 Physician reminders (2 hospitals) versus; 3 Comparison group of physician education (2 hospitals) (Number of clients not provided) | Influenza, 1 versus 2 = 23% change (p < 0.002); 1 versus 3 = 30% (significance not provided); 2 versus 3 = 7% (nonsignificant)
Effects of Provider Education on Knowledge and Attitudes
Freed Ref. 3 1992 | Before/after study; least-suitable, fair | North Carolina; clinics/offices; study population - pediatricians; 73% male, 38% in managed care settings; family practitioners, 83% male, 26% in managed care settings | 1 "National Guidelines for Universal Hepatitis B" and attendant dissemination efforts (591 physicians) versus; 2 Comparison group of prior usual care (478 physicians) | Agreement with universal hepatitis B recommendations, rose from 32%- 62% among pediatricians and 17%-32% among family practitioners
Zimmerman Ref. 4 Time not reported | Before/after study, least-suitable, good | United States; medical schools and residency programs; study population - residents in family practice and pediatrics; medical students | 1 Problem-based learning and multistation clinical teaching versus; 2 Comparison group of prior provider education (20 medical schools; 996 medical students; 126 residents) | Significant improvement in knowledge for all 11 topics with median change of 2.6 items on 10-item test

##### References

Cowan JA, Heckerling PS, Parker JB. Effect of a fact sheet reminder on performance of the periodic health examination: a randomized controlled trial. Am J Prev Med. 1992;8:104-9. [pmid: 1599717].
Crouse BJ, Nichol K, Peterson DC, Grimm MB. Hospital-based strategies for improving influenza vaccination rates. J Fam Pract. 1994;38:258-61. [pmid: 8126406].
Freed GL, Bordley WC, Clark SJ, Konrad TR. Universal hepatitis B immunization of infants: reactions of pediatricians and family physicians over time. Pediatrics. 1994;93:747-51. [pmid: 8165072].
Zimmerman RK, Barker WH, Strikas RA, et al. Developing curricula to promote preventive medicine skills: the Teaching Immunization for Medical Education (TIME) Project. JAMA. 1997;278:705-11. [pmid: 9286828].

### Appendix C Evidence Tables Summarizing Economic Evaluations

Appendix C Nomenclature

AC | average cost
CA | cost-analysis
CE | cost-effectiveness
DT | pediatric formulation of diphtheria and tetanus toxoids
DTP | diphtheria-tetanus toxoids and pertussis vaccine
Hib | Haemophilus influenzae type b conjugate vaccine
MMR | measles, mumps, and rubella vaccine
OPV | oral poliovirus vaccine
Td | adult formulation of diphtheria and tetanus toxoids
WIC | Special Supplemental Nutrition Program for Women, Infants, and Children, which is administered by the U.S. Department of Agriculture

#### Table C-1 Client Reminder/Recall Strongly Recommended

Table C-1 Client Reminder/Recall Strongly Recommended

Table C-1 Client Reminder/Recall Strongly Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Buchner Ref. 1 1984 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Seattle, Washington; general practice; adults aged >65 years; influenza | 1 Mailed client reminder; 2 Control | 1984 US$; costs included direct costs of mailing reminders, including postage, printing, and envelopes; CE ratio of 1 versus 2 = $30/additional vaccination; baseline coverage = 54%; change in coverage = 1% | 1997 US$; CE ratio of 1 versus 2 = $46.35/additional vaccination
Chiu Ref. 2 1994-96 | Cost-analysis; average cost in dollars per child | Jacksonville, Florida; hospital nurseries and communitywide; children aged <18 months; vaccines not specified | 1 "Shots by Two" Project; volunteers "adopt" a baby, introduce themselves, and provide four postcard and phone reminders from the child's birth to age 18 months; 2 No control | 1994 (assumed) US$; estimates do not specify whether per child or per reminder and do not include in-kind contributions of volunteer time; AC = $0.60 /child; county baseline coverage = 64.3%; change in coverage = 16.5% (Entire increase in coverage cannot be attributed to the intervention) | 1997 US$; AC = $0.65/child AC is an underestimate because costs do not include in-kind contribution of volunteer time
Frame Ref. 3 1991-92 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Dansville, New York; rural; family practice; adults aged >21 years; Td booster | 1 Computer-generated provider and client reminders and tracking; 2 Manual tracking | 1992 US$; costs included staff, materials, and postage; cost of installing computer-based system not included; CE ratio = $3.71/additional vaccination; baseline coverage = 20%; change in coverage = 21% | 1997 US$; CE ratio of 1 versus 2 = $4.41/Additional vaccination This intervention also increased provision of other preventive care; therefore, CE ratio probably underestimates overall CE
Frank Ref. 4 1981-82 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Hamilton, Ontario, Canada; urban community health center; adults aged >65 years; influenza | 1 Mailed client reminders; 2 Follow-up telephone calls to nonrespondents; 3 Prior usual care | 1982 (assumed) Canadian$; costs included materials, labor, and postage; CE ratio of 1 versus 3 = $2.16-$2.50/Additional vaccination; CE ratio of 2 versus 1 = $5.00-$8.00/Additional vaccination; baseline coverage = 17%; change in coverage attributable to 1 = 26%; additional change in coverage attributable to 2 = 12% | 1997 US$; CE ratio of 1 versus 3 = $2.80-$3.20/Additional vaccination; CE ratio of 2 versus 1 = $6.40-$10.37/Additional vaccination
Grabenstein Ref. 5 1990 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Durham County, North Carolina; pharmacy-based; adults aged >64 years; influenza | 1 Two mailed reminders regarding risk of influenza and availability of vaccinations; 2 No reminders | 1990 US$; costs included materials, labor, and professional fees; CE ratio of 1 versus 2 = $10.68/Additional vaccination; baseline coverage = 54%; coverage increase = 10% | 1997 US$; CE ratio of 1 versus 2 = $13.00/Additional vaccination
Lieu Ref. 6 1994-95 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Northern California; managed care organization; children aged 20-24 months; MMR | 1 Computer-generated personalized client reminders; 2 Autodialer telephone system; 3 Control group with no reminder | 1996 US$; costs included computer costs, printing, clerical labor, postage, and stationary; baseline coverage = 86%; change in coverage = 4% for both 2 and 3 compared with 1; CE ratio of 1 versus 3 = $4.04/Additional vaccination; CE ratio of 2 versus 3 = $2.14/Additional vaccination | 1997 US$; CE ratio of 1 versus 3 = $4.10/Additional vaccination; CE ratio of 2 versus 3 = $2.18/Additional vaccination Assumes same effectiveness for autodialer system in increasing coverage that was observed for recall letters
Lieu Ref. 7 1996-97 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Northern California; hospital management organization; children aged 20 months; DTP, OPV, MMR, hepatitis B, Hib | Randomized intervention groups 1-4 as follows:; 1 Letter reminder; 2 Automated phone reminder; 3 Letter followed by automated phone reminder; 4 Automated phone reminder and follow-up letter; 5 Nonrandomized comparison group | 1997 US$; costs included computer time, staff time (e.g., programmers and clerical), maintenance of telephone software, postage, telephone fees, software programming (start-up); CE ratio of 1 versus 5 = $10.50/Additional vaccination; using postcard reminders rather than letters would result in CE ratio = $6.50/Additional vaccination if postcards and letters were equally effective; CE ratio of 2 versus 5 = $9.80/Additional vaccination; using lower cost assumptions thought to be consistent with costs at a public clinic would result in a CE ratio of $2.20/Additional vaccination; CE ratio of 3 versus 5 = $7.00/Additional vaccination; CE ratio of 4 versus 5 not reported; baseline up-to-date coverage in the study population not provided; of initially unvaccinated children, 36%-47% were fully vaccinated by age 24 months in the four study groups; change in coverage not calculable from the data presented | 1997 US$; CE ratio of 1 versus 5 = $10.70/Additional vaccination; using postcards rather than letters, CE = $6.70/Additional vaccination; CE ratio of 2 versus 5 = $10.00/Additional vaccination; using lower public clinic cost assumptions would = $2.30/Additional vaccination; CE ratio of 3 versus 5 = $7.20/Additional vaccination
McLeod Ref. 8 1996 | Cost-analysis; average cost in dollars per child | Wellington, New Zealand; convenience sample of noncapitated and capitated practices; preschool-age children; vaccine not specified | 1 Costs of vaccinating preschool-age children among practices participating in a system of audit and feedback and using client recalls and reminders; 2 No comparison group | 1996 New Zealand$; costs included practice nurse and general practitioner labor, materials, supplies, staff, and receptionist labor; cost of vaccine not included; costs of audit and feedback not included; AC = New Zealand$8.51/child; no baseline coverage data; no change in coverage data | 1997 US$; AC = $5.75/child Includes costs of clinical time for providing vaccinations as well as recall; overestimates cost of recall alone
Moran Ref. 9 1991 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Boston, Massachusetts; urban community health center; poor to lower income; aged >65 years or <65 years but at high-risk; influenza | 1 Educational brochure; 2 Lottery-type incentive; 3 Both educational brochure and incentive; 4 Control group of usual care | 1991 (assumed) US$; costs included graphic development, printing, prizes, postage, and clerical labor; costs of vaccine, software, tracking hardware, and student personnel not included; CE ratio of 1 versus 4 = $3.45/Additional vaccination; CE ratio of 2 versus 4 = $8.74/Additional vaccination; CE ratio of 3 versus 4 = $43.06/Additional vaccination; baseline coverage = 20%; coverage increase 1 = 16%, 2 = 9%, and 3 = 6% | 1997 US$; CE ratio of 1 versus 4 = $4.06/Additional vaccination; CE ratio of 2 versus 4 = $10.00/Additional vaccination; CE ratio of 3 versus 4 = $50.73/Additional vaccination
Nexøe Ref. 10 1995 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Denmark; general practices; adults aged >65 years; influenza | 1 Mailed invitation for vaccination; 2 Mailed invitation plus free vaccination; 3 Comparison group of usual care | 1995 US$; costs included postage and vaccination administration; CE ratio of 1 versus 3 = $21.00/Additional vaccination; CE ratio of 2 versus 3 = $40.50/Additional vaccination; includes price of vaccine; baseline coverage = 25%; coverage increase 1 versus 3 = 24%; 2 versus 3 = 47% | 1997 US$; CE ratio of 1 versus 3 = $22.10/Additional vaccination; CE ratio of 2 versus 3 = $43.00/Additional vaccination
Rosser Ref. 11 1983-86 | Cost-effectiveness; cost-effectiveness in dollars per additional vaccination | Ottawa, Canada; University of Ottawa Family Medicine Center at Civic Hospital; adults aged >20 years; tetanus booster | 1 Physician reminder; 2 Telephone reminder by nurse; 3 Letter reminder; 4 Randomized control | 1985 Canadian$ (assumed); direct costs, including medical and nonmedical staff labor, postage, and stationary; cost of producing provider reminders not included; CE ratio of 1 versus 4 = $0.43/Additional vaccination; CE ratio of 2 versus 4 = $5.00/Additional vaccination; CE ratio of 3 versus 4 = $6.50/Additional vaccination; baseline coverage = 3%; change in coverage, 1 = 20%, 2 = 21%, and 3 = 27% | 1997 US$; CE ratio of 1 versus 4 = $0.70/Additional vaccination; CE ratio of 2 versus 4 = $8.75/Additional vaccination; CE ratio of 3 versus 4 = $9.75/Additional vaccination

##### References

Buchner DM, Larson EB, White RF. Influenza vaccination in community elderly: a controlled trial of postcard reminders. J Am Geriatr Soc. 1987;35:755-60. [pmid: 3301990].
Chiu TT, Barata SL, Unsicker DM, Brennan L. Community mobilization for preschool immunizations: the "Shots by Two" project. Am J Public Health. 1997;87:462-3. [pmid: 9096555].
Frame PS, Zimmer JG, Werth PL, Jackson Hall W, Eberly SW. Computer-based vs manual health maintenance tracking: a controlled trial. Arch Fam Med. 1994;3:581-8. [pmid: 7921293].
Frank JW, McMurray L, Henderson M. Influenza vaccination in the elderly: 2. the economics of sending reminder letters. CMAJ. 1985;132:516-21. [pmid: 3971268].
Grabenstein JD, Hartzema AG, Guess HA, Johnston WP, Rittenhouse BE. Community pharmacists as immunization advocates. Cost-effectiveness of a cue to influenza vaccination. Med Care. 1992;30:503-13. [pmid: 1593916].
Lieu TA, Black SB, Ray P, et al. Computer-generated recall letters for underimmunized children: how cost-effective?. Pediatr Infect Dis J. 1997;16:28-33. [pmid: 9002097].
Lieu TA, Capra AM, Makol J, Black SB, Shinefield HR. Effectiveness and cost-effectiveness of letters, automated telephone messages, or both for underimmunized children in a health maintenance organization. Pediatrics. 1998;101. [pmid: 9521970].
McLeod D, Bowie RD, Kljakovic M. Cost of childhood immunization in general practice. N Z Med J. 1998;111:73-6. [pmid: 9549556].
Moran WP, Nelson K, Wofford JL, Velez R, Case LD. Increasing influenza immunization among high-risk patients: education or financial incentive. Am J Med. 1996;101:612-20. [pmid: 9003108].
Nexøe J, Kragstrup J, Rønne T. Impact of postal invitations and user fee on influenza vaccination rates among the elderly: a randomized controlled trial in general practice. Scand J Prim Health Care. 1997;15:109-12. [pmid: 9232713].
Rosser WW, Hutchison BG, McDowell I, Newell C. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146:911-17. [pmid: 1544078].

#### Table C-2 Multicomponent Interventions That Include Education Strongly Recommended

Table C-2 Multicomponent Interventions That Include Education Strongly Recommended

Table C-2 Multicomponent Interventions That Include Education Strongly Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Hand Ref. 1 1979 | Cost-analysis; average cost in dollars per child | Missoula, Montana; 32 schools; children aged <15 years; multiple vaccines but specific vaccines considered not reported | 1 U.S. Department of Health, Education, and Welfare immunization initiative, including (a) task force of community members and school officials identified strategies and worked with the community; (b) press releases developed (media coverage not described); and (c) school-based intervention assessed immunization status and provided vaccinations; 2 No control group | 1979 US$; costs not specified; in-kind time contribution of 900 volunteers probably not included; unclear whether vaccine costs were included in program costs; unclear whether costs of task force or community education were included; AC = $10.75/child; no baseline coverage data included; 35% of children received vaccination = 18% increase in children meeting minimum immunization requirements | 1997 US$; AC of total program = $23.00/child
Westman Ref. 2 1990-92 | Cost-analysis; average cost in dollars per vaccination | Los Angeles County, California; program implemented in a comprehensive health center and the surrounding community; undervaccinated preschoolers; low-income Latino population; no vaccine specified | 1 Multicomponent intervention including (a) assessment of target population's vaccination coverage, community, and clinic needs (b) walk-in vaccination clinic Monday-Friday and Saturday mornings; (c) multiple education and health promotion strategies in the clinic (e.g., puppet shows and educational packets) and in the community (e.g., advertising, appearances on radio programs, and talk shows, and promotional activities in schools and churches); (d) monitoring of rates of children completing a DTP series and of missed opportunities (unclear if this information was fed back to staff); 2 No control group | 1992 US$; costs include vocational nurse, community worker, and clerk salaries and benefits plus overhead for program administration and research activities; report is unclear regarding whether costs of educational material were; average cost = $6.69/vaccination; no baseline coverage data; no coverage increase data | 1997US$; AC of 1 = $7.65/vaccination

##### References

Hand JS, Anderson D, Feffer D, Day CA. Successful school immunization program - or not?. J Sch Health. 1980;50. [pmid: 6897996].
Westman S, Halbert RJ, Walton LG, Henneman CE. A "clinic without walls": the Los Angeles Immunization Demonstration Project. Am J Public Health. 1997;87:293-4. [pmid: 9103117].

#### Table C-3 Vaccination Requirements for Child Care, School, and College Attendance Recommended

No economic evaluations of vaccination requirements for child care, school, and college attendance were identified.

#### Table C-4 Communitywide Education Only Insufficient Evidence

Economic evaluation reviews were not conducted for communitywide education only.

#### Table C-5 Clinic-Based Education Only Insufficient Evidence

Economic evaluation reviews were not conducted for clinic-based education only.

#### Table C-6 Client or Family Incentives Insufficient Evidence

Economic evaluation reviews were not conducted for client or family incentives.

#### Table C-7 Client-Held Medical Records Insufficient Evidence

Economic evaluation reviews were not conducted for client-held medical records.

#### Table C-8 Reducing Out-of-Pocket costs Strongly Recommended

Table C-8 Reducing Out-of-Pocket costs Strongly Recommended

Table C-8 Reducing Out-of-Pocket costs Strongly Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Nexøe Ref. 1 1995 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Denmark; general practices; adults, aged >65 years; influenza | 1 Mailed invitation for vaccination; 2 Mailed invitation plus free vaccination; 3 Comparison group of usual care | 1995 US$; costs included postage and vaccination administration; CE ratio of 1 versus 3 = $21.00/Additional vaccination; CE ratio of 2 versus 3 = $40.50/Additional vaccination, including price of vaccine; baseline coverage = 25%; coverage increase = 1 versus 3 = 24%, 2 versus 3 = 47% | 1997 $US; CE ratio of 1 versus 3 = $22.10/Additional vaccination; CE ratio of 2 versus 3 = $43.00/Additional vaccination

##### References

Nexøe J, Kragstrup J, Rønne T. Impact of postal invitations and user fee on influenza vaccination rates among the elderly: a randomized controlled trial in general practice. Scand J Prim Health Care. 1997;15:109-12. [pmid: 9232713].

#### Table C-9 Expanding Access in healthcare Settings Strongly Recommended as part of Multicomponent Intervention Insufficient Evidence When Used Alone

Table C-9 Expanding Access in healthcare Settings Strongly Recommended as part of Multicomponent Intervention Insufficient Evidence When Used Alone

Table C-9 Expanding Access in healthcare Settings Strongly Recommended as part of Multicomponent Intervention Insufficient Evidence When Used Alone

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Westman Ref. 1 1990-92 | Cost-analysis; average cost in dollars per vaccination | Los Angeles County, California; program implemented in a comprehensive health center and the surrounding community; undervaccinated preschoolers; low-income Latino population; no vaccine specified | 1 Multicomponent intervention including (a) assessment of target population's vaccination coverage, community, and clinic needs (b) walk-in vaccination clinic Monday-Friday and Saturday mornings; (c) multiple education and health promotion strategies in the clinic (e.g., puppet shows and educational packets) and in the community (e.g., advertising, appearances on radio programs, and talk shows, and promotional activities in schools and churches); (d) monitoring of rates of children completing a DTP series and of missed opportunities (unclear if this information was fed back to staff); 2 No control group | 1992 US$; costs include vocational nurse, community worker, and clerk salaries and benefits plus overhead for program administration and research activities; report is unclear regarding whether costs of educational material were; average cost = $6.69/vaccination; no baseline coverage data; no coverage increase data | 1997US$; AC of 1 = $7.65/vaccination

##### References

Westman S, Halbert RJ, Walton LG, Henneman CE. A "clinic without walls": the Los Angeles Immunization Demonstration Project. Am J Public Health. 1997;87:293-4. [pmid: 9103117].

#### Table C-10 Vaccination Programs in WIC Settings Recommended

Table C-10 Vaccination Programs in WIC Settings Recommended

Table C-10 Vaccination Programs in WIC Settings Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Flatt Ref. 1 1993-95 | Cost-analysis; average cost in dollars per assessment | Dallas, Texas; inner-city children; multivaccine | Five components of Women, Infants, and Children (WIC) program interventions were tested using immunization assessment plus one or more of; 1 on-site WIC vaccination nurse;; 2 colocated vaccination clinic;; 3 voucher restriction; or; 4 outside referral for vaccination | 1994-95 US$; costs included clerical and nurse salaries, computer hardware, and miscellaneous supplies; AC of assessment plus 1 = $2.45/assessment; AC of assessment plus 2, 3, or 4 = $1.18/assessment; baseline coverage and change in coverage not calculable from the information provided | 1997 US$; AC of assessment plus 1 = $2.65/assessment; AC of assessment plus 2, 3, 4 = $1.28/assessment
Hutchins Ref. 2 1991-93 | Cost-effectiveness; cost-effectiveness ratio in dollars per fully vaccinated child | Chicago, Illinois; WIC sites; children aged<5 years; urban; low socioeconomic status; DTP, OPV, MMR | Assessment of immunization status plus voucher restriction plus free vaccines plus referral to; 1 On-site nurse or; 2 On-site clinic or; 3 Off-site clinic; 4 Comparison group of usual care | 1994 US$; costs included assistant and nurse salaries, computer, printer and supplies; vaccine provided free of charge by Chicago Department of Health; CE ratio of 1 versus 4 = $73.00/Additional vaccination; CE ratio of 2 versus 4 = $37.00/Additional vaccination; CE ratio of 3 versus 4 = $30.00/Additional vaccination | 1997 US$; CE ratio of 1 versus 4 = $84.00/Additional vaccination; CE ratio of 2 versus 4 = $42.00/Additional vaccination; CE ratio of 3 versus 4 = $34.00/Additional vaccination

##### References

Flatt K, Watson J C, Anderson KN, Logan L, and Nguyen VA. Cost comparison of methods used to increase immunization levels at a WIC setting [abstract 3299]. Presented at American Public Health Association Conference, November 1996, New York, NY.
Hutchins S, Luna H, Ferguson D. Rosenthal J. Hadler S. Cost-effectiveness of linking WIC and vaccination services [abstract]. In: Abstracts of the American Public health Association 122nd Annual Meeting. Washington DC: American Public Health Association; 1994:174.

#### Table C-11 Home Visits Recommended

Table C-11 Home Visits Recommended

Table C-11 Home Visits Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Jefferson Ref. 1 1985-86 | Cost analysis; average cost in dollars per child vaccinated | Oxford, England; children aged 3 months-18 years; DT, pertussis, measles, rubella, poliovirus | 1 Home visit and provision of vaccination in homes by a vaccination nurse; 2 No control group | 1985 British £; costs included staff nurse salary, expenses and milage; costs of identifying appropriate children not included; AC = £8/vaccination; no baseline coverage data; no increase in coverage data; the nurse also provided services not limited to vaccination; thus, cost estimates might slightly overestimate costs of home visits to improve vaccination coverage | 1997 US$; AC of 1 = $21.50/child vaccinated Limited to the city limits of a small city; therefore, probably underestimates costs for either larger metropolitan areas or rural areas
Jones Ref. 2 1961-83 | Cost analysis; average cost in dollars per vaccination | Manchester, England; preschool-age children; DT or DTP, OPV, measles, pertussis | 1 Home visiting by nurse and physician for families that had failed to bring children to be vaccinated by a practitioner; 2 No control | 1982 British £; costs include salary of nurse, travel, and the equivalent of 46 sessions/year of a clinical medical officer; costs of identifying appropriate children not included; average cost = £41/vaccination; baseline coverage = 78%; coverage increase not reported | 1997 US$; AC = $130.00/vaccination
Rodewald Ref. 3 1994-95 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional fully vaccinated child | Rochester, New York; primary-care practices; clients enrolled from birth to age 1 year and followed for 18 months; urban/rural; DTP, OPV, MMR, Hib | 1 Lay community services provider made phone, mail, or home contact; 2 Provider education, feedback, and reminders; 3 Usual care | 1994 (assumed) US$; costs included outreach worker and supervisor salaries, fringe benefits, and materials; CE ratio of 1 versus 3 = $474.00/fully vaccinated child; CE ratio of 2 versus 3 not reported | 1997 US$; CE ratio of 1 versus 3 = $513.00/Additional vaccination The intervention also improved some other health outcomes (e.g., lead screening) that are not reflected in the CE ratio
Wood Ref. 4 1994 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Los Angeles, California; lower income inner-city; children aged <1 year; black; urban; DTP/OPV/Hib | 1 In-depth assessment before infants were age 6 weeks, home visits, and additional follow-up; 2 Comparison group of usual care | 1994 US$; costs included personnel, supplies, travel, office space, and orientation; CE ratio of 1 versus 2 = $12,022.00/Additional vaccination; baseline coverage = 51%; change in coverage = 13% | 1997 US$; CE ratio of 1 versus 2 = $13,020/Additional vaccination

##### References

Jefferson N, Sleight G, Macfarlane A. Immunisation of children by a nurse without a doctor present. BMJ. 1987;294:423-4. [pmid: 3101907].
Jones AE. Domiciliary immunisation for preschool child defaulters. BMJ. 1984;289:1429-31. [pmid: 6437585].
Rodewald LE, Szilagyi PG, Humiston SG, Barth R, Kraus R, Raubertas RF. Randomized study of tracking with outreach and provider prompting to improve immunization coverage and primary care. Pediatrics. 1999;103:31-8. [pmid: 9917436].
Wood D, Halfon N, Donald-Sherbourne C, et al. Increasing immunization rates among inner-city, African American children: a randomized trial of case management. JAMA. 1998;279:29-34. [pmid: 9424040].

#### Table C-12 Vaccination programs in Schools Insufficient Evidence

Economic evaluation reviews were not conducted for vaccination programs in schools.

#### Table C-13 Vaccination Programs in Child Care Centers Insufficient Evidence

Economic evaluation reviews were not conducted for vaccination programs in child care centers.

#### Table C-14 Provider Reminder/Recall Strongly Recommended

Table C-14 Provider Reminder/Recall Strongly Recommended

Table C-14 Provider Reminder/Recall Strongly Recommended

Author, Reference Number, Study Period | Analytic Method, Reported or Calculated Summary Measure | Study Location, Setting Type, Population Description, Vaccine | Interventions Studied, Comparisons | Base Year, Costs Included, Reported Summary Measure, Coverage Baseline and Increase | Adjusted Base Year, Summary Measure Adjusted Value, Notes
Bell Ref. 1 1994-95 | Cost-effectiveness; cost-effectiveness ratio in dollars per fully vaccinated child | Philadelphia, Pennsylvania; children's hospital; hospitalized preschool-age children; OPV, DTP, MMR, Hib | 1 Hospital-based program to assess children's immunization status, including verification of immunization status with primary-care providers, and generate provider reminders; 2 Prior usual care | 1994 (assumed) US$; costs included physician, nurse, coordinator, and assistant's salaries; $270.00/fully vaccinated child; baseline coverage = 44%; coverage increase = 26% | 1997 US$; AC = $300.00/fully vaccinated child
Frame Ref. 2 1991-92 | Cost-effectiveness; cost-effectiveness in dollars per additional vaccination | Dansville, New York; rural family practice; adults aged >21 years; Td booster | 1 Computer-based provider and client reminders tracking; 2 Manual tracking | 1992 US$; costs of provider and client reminders included staff, materials, and postage; cost of installing computer-based system not included; CE ratio = $3.71/Additional vaccination; baseline coverage = 20%; change in coverage = 21% | 1997 US$; CE ratio of 1 versus 2 = $4.41/Additional vaccination The intervention also improved some other health outcomes (e.g., provision of screening tests) that are not reflected in the CE ratio
Rosser Ref. 3 1983-86 | Cost-effectiveness; cost-effectiveness ratio in dollars per additional vaccination | Ottawa, Canada; University of Ottawa Family Medicine Center at Civic Hospital; adults aged >20 years; tetanus booster | 1 Physician reminder; 2 Telephone reminder by nurse; 3 Letter reminder; 4 Randomized control | 1985 Canadian$ (assumed); direct costs, including medical and nonmedical staff time, postage, stationary; cost of producing provider reminders not included; CE ratio of 1 versus 4 = $0.43/fully vaccinated child; CE ratio of 2 versus 4 = $5.00/fully vaccinated child; CE ratio of 3 versus 4 = $6.50/fully vaccinated child; baseline coverage = 3%; change in coverage, 1 = 20%, 2 = 21%, and 3 = 27% | 1997 US$; CE ratio of 1 versus 4 = $0.70Â¢/fully vaccinated child; CE ratio of 2 versus 4 = $8.75/fully vaccinated child; CE ratio of 3 versus 4 = $9.75/fully vaccinated child

##### References

Bell LM, Pritchard M, Anderko R, Levenson R. Program to immunize hospitalized preschool-aged children: evaluation and impact. Pediatrics. 1997;100:192-6. [pmid: 9240798].
Frame PS, Zimmer JG, Werth PL, Jackson Hall W, Eberly SW. Computer-based vs manual health maintenance tracking: a controlled trial. Arch Fam Med. 1994;3:581-8. [pmid: 7921293].
Rosser WW, Hutchison BG, McDowell I, Newell C. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146:911-17. [pmid: 1544078].

#### Table C-15 Assessment and Feedback for Vaccination Providers Strongly Recommended

No economic evaluations of assessment and feedback for vaccination providers were identified.

#### Table C-16 Standing Orders Strongly Recommended for Adults Insufficient Evidence for Children

No economic evaluations of standing orders were identified.

#### Table C-17 Provider Education Only Insufficient Evidence

Economic evaluation reviews were not conducted for provider education only.