# Recommendations Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke

Medical Subject Headings (MeSH): community health services; decision-making; evidence-based medicine; practice guidelines; preventive health services; public health practice; smoking cessation; meta-analysis; review literature; tobacco smoke pollution; tobacco use cessation.

## Introduction

Tobacco use is the single largest cause of preventable premature death in the United States, ^1, ^ ^2, ^ ^3^ and exposure to environmental tobacco smoke (ETS) is a preventable cause of significant morbidity and mortality. ^4, ^ ^5, ^ ^6^ Preventing tobacco use in children and adolescents, reducing tobacco use in adults, and reducing nonsmokers' exposure to ETS are essential public health objectives for communities. This report makes recommendations on the evidence of effectiveness of selected community and health care system interventions in achieving these objectives.

The recommendations in this report represent the work of the independent, nonfederal Task Force on Community Preventive Services (the Task Force). The Task Force is developing the Guide to Community Preventive Services (the Community Guide ) with the support of the U.S. Department of Health and Human Services (DHHS) in collaboration with public and private partners. The Centers for Disease Control and Prevention (CDC) provides staff support to the Task Force for development of the Community Guide. Although the recommendations presented in this report were developed by the Task Force and are not the recommendations of CDC or DHHS, they are consistent with and complementary of the recommendations recently put forth by the Public Health Service, ^7^ DHHS, ^8^ and CDC. ^9^

This report provides recommendations on interventions to reduce tobacco use and ETS exposure. These recommendations present options appropriate for communities and health care systems, as well as state and national programs. The reviews of evidence underlying these recommendations are provided in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke). The methods of conducting evidence reviews and translating the evidence of effectiveness into recommendations for the Community Guide have been published. ^10^

## Interpreting and Using the Recommendations

Given that tobacco use is the largest preventable cause of premature death in the United States, reducing tobacco use and ETS exposure are important goals to most communities. In selecting and implementing interventions, it is recommended that communities develop and maintain a comprehensive, multifaceted strategy to reduce exposure to ETS, reduce tobacco use initiation, and increase tobacco use cessation. Improvements in each category will contribute to reductions in tobacco-related morbidity and mortality, and success in one area may contribute to improvements in the other areas as well. Increasing tobacco use cessation, for example, will reduce exposure to ETS, and smoking bans, effective in reducing exposure to ETS, may also reduce some tobacco users' daily tobacco consumption and assist others in quitting entirely. Although the Task Force has provided assessments for individual interventions or intervention combinations, comprehensive community efforts will require the implementation of multiple interventions to address tobacco use and exposure to ETS in diverse settings and populations. The recommendations provided in this report can assist communities in assembling a comprehensive program consisting of interventions with demonstrated evidence of effectiveness.

Choosing interventions that have been shown to work and that are well matched to local needs and capabilities, and then implementing those interventions well, are important steps in establishing a comprehensive community program. In setting priorities for the selection of interventions to meet local objectives, recommendations provided in the Community Guide and other information, such as the range of observed effect sizes and effectiveness in different target populations and groups, should be considered along with such local information as resource availability, administrative structures, and economic, social, and regulatory environments of available organizations and practitioners. Information regarding applicability (provided for each intervention in the accompanying article, Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke) can be used to assess the extent to which the intervention might be useful in a particular local setting or population. Although the Task Force recognizes the importance of implementing interventions tailored to resonate with the target population, the specifics of these efforts, in most cases, was considered outside of the Community Guide mandate. Economic information (also provided in the accompanying article, Appendix C), though limited, may be useful in identifying (1) resource requirements for interventions, and (2) interventions that meet public health goals more efficiently than other available options for reaching the same goals.

The Task Force recommendations are based primarily on the evidence of effectiveness of interventions as implemented, evaluated, reported, and published. A Task Force finding of insufficient evidence does not imply evidence of ineffectiveness of the intervention, but does identify areas of uncertainty and specific continuing research needs. In these instances it should not be inferred that the targeted outcomes are not important in a comprehensive community effort. The evidence of effectiveness of community education efforts to reduce ETS exposure in the home environment, for example, was evaluated as insufficient based on the lack of qualifying studies. The Task Force assessment nevertheless recognizes the importance of efforts to reduce ETS exposure in the home, the primary source of exposure for infants and children. ^11^

A starting point for communities and health care systems is an assessment of current tobacco use prevention and control activities. Current efforts should be compared with recommendations in this report as well as other relevant program recommendations proposed by CDC, ^9^ the National Cancer Institute (NCI), ^12^ the Public Health Service (PHS), ^7^ DHHS, ^8, , ^ ^13, , ^ ^14^ and the Institute of Medicine. ^15, , ^ ^16^ In addition to assessing overall progress toward goals, health planners must identify and address the community differences in tobacco use and ETS exposure that contribute to disparities in health. The implementation of effective interventions tailored to settings and populations with higher prevalence rates of tobacco use, such as low socioeconomic populations and some racial/ethnic groups, ^9, ^ ^14, ^ ^17^ is important to the success of comprehensive tobacco control efforts.

This review did not examine the evidence of effectiveness of clinical cessation programs or therapies for tobacco dependence (such as pharmacologic treatments), which are not part of the Community Guide mandate but were addressed in an extensive, evidence-based review recently updated by the PHS. ^7^ However, the evidence reviews conducted for the Community Guide include several health care system interventions, such as provider reminder systems and patient telephone cessation support, that can help health care providers identify, advise, and/or assist tobacco-using patients in their efforts to quit. The recommendations in the Community Guide complement those provided in the PHS Clinical Practice Guideline, and both present a range of effective options for increasing and improving patient tobacco use cessation.

## Intervention Recommendations

The Task Force evaluated the evidence of effectiveness of 14 selected interventions, presented here in three sections: (1) strategies to reduce exposure to environmental tobacco smoke; (2) strategies to reduce tobacco use initiation; and (3) strategies to increase tobacco use cessation. Evaluations of three additional interventions are still in progress (described in Additional Reviews, below).

### Strategies to Reduce Exposure to Environmental Tobacco Smoke

This section covers interventions reviewed by the Task Force, which can directly reduce or eliminate exposure to environmental tobacco smoke. Although community efforts to increase cessation and reduce initiation of tobacco use will also eventually reduce ETS exposures, additional interventions are necessary to provide immediate protection for nonsmokers in workplaces, public areas, and home environments. This section includes an evaluation of the effectiveness of smoking bans and restrictions implemented as workplace policies, organization regulations, community ordinances, and state law, and an evaluation of community education efforts to increase voluntary adoption of smoking policies in households.

#### Smoking bans and restrictions- Strongly recommended

Smoking bans and restrictions are policies and regulations that ban or limit the consumption of tobacco products in designated areas. These include private business and employer policies, organization regulations, and government laws and ordinances. Laws and ordinances can establish minimum standards to protect workers in private-sector workplaces, as well as ban or restrict smoking in public areas and workplaces.

Smoking bans and restrictions are strongly recommended on the basis of strong scientific evidence that they reduce exposure to ETS: (1) in a wide range of workplace settings and adult populations; (2) when applied at different levels of scale, from individual businesses to entire communities; and (3) whether used alone or as part of a multicomponent community or workplace intervention. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

In addition to evidence of effectiveness in reducing workplace exposure to ETS, several qualifying studies observed a significant reduction in daily consumption of cigarettes by workers subject to a smoking ban or restriction. Some of the qualifying studies that evaluated smoking bans observed increases in tobacco use cessation and/or reductions in tobacco use prevalence in their study populations.

#### Community education-Insufficient evidence

Community education provides information to parents, other occupants, and visitors to the home about the importance of reducing or eliminating ETS to protect nonsmoking adults and children. Education interventions attempt to motivate household members to modify smoking habits to reduce exposure of nonsmokers to indoor ETS (by establishing home policies restricting or banning smoking) if they cannot quit entirely.

The Task Force review identified only one qualifying study of community-wide education interventions including an ETS component, an insufficient number of studies for assessing the effectiveness of the intervention. Details of the qualifying study are provided in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke). A recent review of efforts to reduce children's exposure to ETS reached a similar conclusion. ^11^

### Strategies to Reduce Tobacco Use Initiation

In this section, the Task Force reviewed interventions to reduce tobacco use initiation among children, adolescents, and young adults. Most smokers initiate tobacco use during childhood and adolescence, and nicotine addiction begins during the first few years of use. ^15^ Major risk factors for tobacco use initiation among children and adolescents are perceptions that tobacco use is a common and normative peer and adult behavior, and the availability and accessibility of tobacco products. ^13^ Although recent studies have identified increases in tobacco use prevalence in populations of young adults such as college students, ^18^ overall, if adolescents are kept tobacco-free, most will never start using tobacco. ^13^ This report includes evaluations of two interventions to achieve this goal. Evaluations of three additional interventions are still in progress (described in Additional Reviews, below).

#### Increasing the unit price for tobacco products- Strongly recommended

Interventions to increase the unit price for tobacco products include legislation at the state or national level to raise the product excise tax. Although other factors also affect tobacco product pricing, excise tax increases historically have resulted in equivalent or larger increases in tobacco product price. ^19^

Interventions to increase the price of tobacco products are strongly recommended by the Task Force based on strong evidence of effectiveness in reducing tobacco use prevalence in study populations of adolescents and young adults. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke). In addition, increasing the price for tobacco products is also effective in: (1) reducing population consumption of tobacco products, and (2) increasing tobacco use cessation (described below in the section, Strategies to Increase Tobacco Use Cessation).

#### Mass media campaigns-Strongly recommended (when combined with other interventions)

Campaigns are mass media interventions of an extended duration, using brief, recurring messages to inform and to motivate children and adolescents to remain tobacco-free. Message content is developed through formative research, and message dissemination includes the use of paid broadcast time or print space (as advertisements), donated time and space (as public service announcements), or a combination of paid and donated time and space.

None of the studies identified in this review evaluated the impact of campaigns implemented alone. Therefore, the Task Force evaluated the evidence of effectiveness of mass media campaigns when implemented with additional interventions, such as tobacco product excise tax increases, school-based education, or other community programs. In most of the evaluated studies, however, the media campaign was the dominant intervention implemented.

Mass media campaigns are strongly recommended by the Task Force based on strong evidence of effectiveness in reducing tobacco use prevalence among adolescents when implemented in combination with tobacco price increases, school-based education, and/or other community education programs. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

### Strategies to Increase Tobacco Use Cessation

The Task Force evaluated a wide range of interventions to increase cessation among tobacco product users. Efforts to increase cessation include strategies to increase the number of tobacco users who attempt to quit, strategies to increase the frequency of these cessation attempts, strategies to improve the success rate of individual cessation attempts, and strategies to achieve all of these goals.

#### Increasing the unit price for tobacco products- Strongly recommended

Interventions to increase the unit price of tobacco products include state and federal legislation raising the excise tax on these products. Although other factors also affect tobacco product pricing, excise tax increases historically have resulted in equivalent or larger increases in tobacco product prices. ^19^

Interventions to increase the price of tobacco products are strongly recommended by the Task Force based on strong evidence of effectiveness in: (1) reducing population consumption of tobacco products; (2) reducing tobacco use initiation (described above in the section on Strategies to Reduce Tobacco Use Initiation); and (3) increasing tobacco cessation. Excise tax increases demonstrated evidence of effectiveness in a variety of populations and when implemented at both the national and state levels. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

### Mass media education

These community-wide interventions provide tobacco product users with cessation information and motivation to quit, through the use of broadcast and print media. The Task Force review of the available evidence distinguished among three types of mass media interventions (campaigns, cessation series, and cessation contests) that differ in the duration, intent, and intensity of the media messages.

#### Campaigns-Strongly recommended (when combined with other interventions).

Campaigns are mass media interventions of an extended duration, using brief, recurring messages to inform and to motivate tobacco product users to quit. Message content is developed through formative research, and message dissemination includes the use of paid broadcast time and/or print space (as advertisements), donated time and space (as public service announcements), or a combination of paid and donated time and space.

None of the studies identified in this review evaluated the impact of campaigns when implemented alone. Therefore, the Task Force evaluation of the evidence of effectiveness concerns mass media campaigns when implemented with additional interventions, such as excise tax increases, and other community education efforts. In several studies, however, the mass media campaign was the dominant intervention implemented.

Multicomponent interventions that include a mass media campaign are strongly recommended by the Task Force based on strong evidence of effectiveness in (1) reducing population consumption of tobacco products, and (2) increasing cessation among tobacco product users. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke). The Task Force recommendation is based primarily on the effectiveness of long-duration, high-intensity campaigns implemented and evaluated in three states (California, Massachusetts, and Oregon) in which use of mass media was coordinated with an excise tax increase and funding for other community and school-based education programs. These campaigns used messages developed through formative research, and purchased broadcast time and print space.

#### Cessation series-Insufficient evidence.

Cessation series are mass media interventions using recurring instructional segments to recruit, inform, and motivate tobacco product users to initiate and to maintain cessation efforts. Cessation series can be coordinated with pre-series broadcast or print promotion, community education such as distribution of self-help cessation materials, and organization of cessation groups in the community. The series can extend for a period of several weeks to several months, and can be delivered as nightly or weekly segments on news or informational broadcasts, which provide expert advice or peer group experiences on a variety of cessation issues (for example, dealing with the symptoms of withdrawal).

Based on available scientific evidence, the Task Force found insufficient evidence to assess the effectiveness of cessation series. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke). The available evidence was deemed insufficient on the basis of (1) inadequate comparison populations or groups, and (2) inconsistent results.

#### Cessation contests-Insufficient evidence.

Cessation contests are short-duration, community-wide events using mass media for the promotion, recruitment, and motivation of tobacco product users to commit to quit on a targeted cessation date or during a specified period. The Task Force evaluation included contests that offered additional incentives for participation and successful cessation, as well as targeted quit events conducted without additional incentives.

The Task Force review identified only one qualifying study of cessation contests, an insufficient number of studies for assessing the effectiveness of the intervention. Most of the identified studies provided assessments of cessation rates in contest participants without a comparison population or group. The Task Force conclusion was based on (1) too few studies, and (2) insufficient comparison/control groups. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

### Health care system-level interventions

The Task Force reviewed a variety of interventions, appropriate for use by health care providers and systems, which were implemented to increase or improve patient tobacco use cessation. The effectiveness of provider counseling to tobacco-using patients and specific clinical therapies (such as nicotine replacement), as documented in the PHS Treating Tobacco Use and Dependence: Clinical Practice Guideline, ^7^ enabled the Task Force to expand the criteria for measurements of effectiveness in the evaluation of interventions in this subsection. In addition to measurements of changes in patient tobacco use cessation, the Task Force considered measurements of changes in provider delivery of advice to quit, and changes in patient use of effective cessation therapies (such as nicotine replacement).

#### Provider reminders-Recommended.

Provider reminders involve efforts to identify tobacco product-using patients and to prompt providers to discuss and/or advise patients on cessation. Techniques by which reminders are delivered include chart stickers, vital sign stamps, medical record flow sheets, and checklists. The content of provider reminders can vary, and provider reminder systems are often combined with other interventions, such as provider education and patient education. These multicomponent interventions are considered separately below.

Based on sufficient scientific evidence of effectiveness in increasing provider delivery of advice to quit, provider reminders are recommended : (1) whether used alone or as part of a multicomponent intervention (see section on Provider reminder + provider education, with or without patient education, below); (2) across a range of intervention characteristics (chart stickers, checklists, and flowcharts); and (3) in a variety of clinical settings and populations. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

#### Provider education-Insufficient evidence.

Provider education involves giving information about tobacco and tobacco use cessation to providers, to increase their knowledge or change their attitudes. Techniques by which information is delivered include lectures, written materials, videos, and continuing medical education seminars. Provider populations include physicians, nurses, physician assistants, health care students, and other office staff. Provider education efforts are frequently combined with other interventions, such as provider reminders and patient education efforts. These multicomponent interventions are considered separately below.

After a review of the scientific evidence, the Task Force found insufficient evidence to assess the effectiveness of provider education alone. The Task Force considered the available evidence insufficient on the basis of (1) inconsistent results in increasing provider advice to quit, and (2) an insufficient number of studies measuring differences in patient cessation. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

#### Provider reminder + provider education, with or without patient education-Strongly recommended.

Multicomponent efforts to increase tobacco use cessation include implementation of provider reminders and efforts to educate providers to identify and to intervene with tobacco-using patients, as well as to provide supplementary educational materials when indicated.

Multicomponent interventions that include a provider reminder system and a provider education program, with or without educational materials for tobacco-using patients, are strongly recommended on the basis of strong evidence that this combination (1) increases provider delivery of advice to quit to tobacco-using patients, and (2) increases patient tobacco use cessation. The Task Force recommendation reflects the evidence of effectiveness of the most common combination evaluated, as the contribution of the individual components to overall effectiveness of these interventions could not be determined. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

#### Provider feedback-Insufficient evidence.

Feedback interventions use assessment of provider performance in delivering tobacco use cessation information or advice to patients, to inform and motivate providers. Retrospective assessments are conducted through chart reviews or computerized medical records. Assessment and feedback interventions can also involve other activities, such as provider education, and these combinations are considered in this section.

After a review of the scientific evidence, the Task Force found insufficient evidence to assess the effectiveness of provider feedback when used alone or in combination with other interventions. The Task Force considered the evidence insufficient on the basis of (1) the small number of studies (n=3), and (2) an insufficient number of studies providing measurements of changes in provider advice to quit or measurements of changes in patient tobacco use cessation. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

#### Reducing patient out-of-pocket costs for effective cessation therapies-Recommended.

This intervention includes efforts to reduce the financial barriers to patient use of cessation therapies that have previously demonstrated evidence of effectiveness. Techniques include providing the services within the health care system, or providing coverage to or reimbursement of patients for expenditures on cessation groups, or on nicotine replacement or other pharmacological therapies.

Reducing patient out-of-pockets costs for effective cessation therapies is recommended by the Task Force on the basis of sufficient scientific evidence of effectiveness in (1) increasing use of the effective therapy, and (2) increasing the total number of tobacco-using patients who quit. A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

#### Multicomponent patient telephone support-Strongly recommended.

Patient telephone support interventions provide tobacco product users with cessation counseling or assistance in attempting to quit and to maintain abstinence. Telephone support can be reactive (tobacco user initiates contact) or proactive (provider initiates contact or user initiates contact with provider-initiated follow-up). Techniques for delivery of telephone support include the use of trained counselors, health care providers, or taped messages in single or multiple sessions. Telephone support sessions usually follow a standardized protocol for providing advice and counseling. The telephone support component is usually combined with other interventions, such as patient educational materials, formal individual or group cessation counseling, or nicotine replacement therapies.

Multicomponent cessation interventions that include telephone support are strongly recommended by the Task Force based on a strong body of evidence that this combination intervention (1) increases patient tobacco cessation, and (2) is effective in both clinical settings and when implemented community-wide. It was not possible in this evaluation to determine the effect of the telephone support component alone. The minimum effective combination evaluated by the Task Force was community-wide, proactive telephone support (proactive follow-up) combined with patient education materials. ^20^ A detailed description of the evidence can be found in the accompanying article (Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke).

## Additional Reviews

The Task Force is currently reviewing the evidence of effectiveness of three additional interventions. Youth access restrictions include laws that regulate and enforce bans on the sale to, or purchase or consumption of tobacco products by, children or adolescents. School-based education includes all efforts to educate and motivate students to remain tobacco-free. Tobacco industry restrictions concern laws that regulate tobacco product content, labeling, promotion, and advertising. Completion and release of the Task Force evaluations and conclusions are anticipated later this year.

## References

1 McGinnis JM, Foege WH. Actual causes of death in the United States. JAMA. 1993;270:2207-12. [pmid: 8411605].
2 National Cancer Institute (US) Smoking and Tobacco Control Program. Changes in cigarette related disease risks and their implication for prevention and control. Bethesda, MD: National Institutes of Health, National Cancer Institute, 1997. Smoking and Tobacco Control Monograph 8.
3 US Department of Health and Human Services. Reducing the health consequences of smoking: 25 years of progress. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, CDC, 1989. DHHS publication no. (CDC) 89-8411.
4 California Environmental Protection Agency. Health effects of exposure to environmental tobacco smoke-Final report and appendices. Sacramento: California Environmental Protection Agency, Office of Environmental Health Hazard Assessment, 1997.
5 US Environmental Protection Agency. Respiratory health effects of passive smoking: Lung cancer and other disorders. Washington, DC: US Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, 1992. EPA/600/6-90/006F.
6 US Office on Smoking and Health. The health consequences of involuntary smoking. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, Centers for Disease Control, Center for Health Promotion and Education, Office on Smoking and Health, 1986. DHHS publication no. (CDC) 87-8398.
7 Fiore MC, Bailey WC, Cohen SJ, et al. Treating tobacco use and dependence. http://www.surgeongeneral.gov/tobacco. Accessed on July 13, 2000.
8 US Department of Health and Human Services. Reducing tobacco use: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, Office on Smoking and Health, 2000.
9 Centers for Disease Control and Prevention. Best practices for comprehensive tobacco control programs-August 1999. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1999.
10 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services-Methods. Am J Prev Med. 2000;18 (Suppl 1S):35-43. [pmid: 10806978].
11 Hovell MF, Zakarian JM, Wahlgren DR, Matt GE. Reducing children's exposure to environmental tobacco smoke: the empirical evidence and directions for future research. Tob Control. 2000;9(Suppl II):ii40-ii47. [pmid: 10841590].
12 US Department of Health and Human Services. Strategies to control tobacco use in the United States: A blueprint for public health action in the 1990's. Bethesda, MD: US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute, 1991. NIH publication no. 92-3316.
13 US Department of Health and Human Services. Preventing tobacco use among young people: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.
14 US Department of Health and Human Services. Tobacco use among US racial/ethnic minority groups-African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
15 Institute of Medicine. Growing up tobacco free: Preventing nicotine addiction in children and youths. Washington, DC: National Academy Press, 1994.
16 National Cancer Policy Board, Institute of Medicine and Commission on Life Sciences-National Research Council. Taking action to reduce tobacco use. Washington, DC: National Academy Press, 1998.
17 US Department of Heath and Human Services. The health benefits of smoking cessation. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1990. DHHS publication no. (CDC) 90-8416.
18 Wechsler H, Rigotti NA, Gledhill-Hoyt J, Lee H. Increased levels of cigarette use among college students: a cause for national concern. JAMA. 1998;280:1673-8. [pmid: 9831998].
19 Chaloupka F, Warner K. The economics of smoking. In: Culyer AJ, Newhouse JP, eds. Handbook of Health Economics. Vol 1B. Amsterdam: Elsevier Science, 2000:1539-627.
20 Zhu SH, Stretch V, Balabanis M, Rosbrook B, Sadler G, Pierce JP. Telephone counseling for smoking cessation: Effects of single-session and multiple-session interventions. J Consult Clin Psychol. 1996;64:202-11. [pmid: 8907100].

## Appendix C: Interpreting the Economic Data

Choosing among community-based preventive interventions entails considering such factors as community needs and goals, effectiveness, cost-effectiveness, equity, feasibility, and other social concerns. However, cost-effectiveness is a useful tool for allocating resources among competing preventive services. Thus, bowing to budgetary constraints, selecting options that are more, rather than less, cost-effective could actually result in greater improvements in health.

In general, the economic data reported in the Community Guide are most appropriate for comparing interventions aimed at achieving the same goals, such as reducing tobacco-related illnesses. For example, adjusted program costs per quitter (Figure C-1) are relatively close for the three interventions for which we have data and, although mass media campaigns are relatively more costly than reducing patient out-of-pockets costs, the difference is small.

Figure C-1: Adjusted program cost per quitter of three interventions for tobacco use prevention, by author

Comparing the cost-effectiveness of interventions in the Community Guide to other preventive interventions requires caution because cost-utility analysis is limited in addressing the efficiency of the allocation of resources from a societal point of view. To paraphrase Gerard and Mooney, ^1^ if a health care decision maker wishes to take a societal view, then the opportunity cost associated with alternative preventive interventions can no longer be restricted to quality-adjusted life years (QALYs), and the relevant form of analysis ceases to be cost-utility and becomes cost-benefit analysis. With that caveat in mind, three interventions for which we have data (Figure C-2)-tobacco use initiation mass media campaigns, cessation mass media campaigns, and patient telephone support for adult smokers-were all in the lower end of the cost-saving-to-$1,024,000/QALY range reported for other preventive services. ^2^ However, the estimation of the ratios reported in the Community Guide did not include the offsetting costs (i.e., benefits) from averting disease caused by tobacco smoke. Had the estimation of the ratios included those benefits, and using Oster's ^3^ range of cost of illness, updated to 1997 values (range from $155,466 for a male smoker aged 35-39 who smoked more than two packs per day to $2,652 for a female smoked aged 75-79 who smoked less than one pack per day), all three interventions would have been shown to be cost-saving.

Figure C-2. Adjusted program costs per quality-adjusted life year (QALY) for tobacco use prevention interventions, by author

There are also limitations to both the studies and our adjustment processes. Even generally similar interventions will vary in the exact activities that are included. For example, the two studies included in the mass media review for this chapter both had a mass media campaign, but only one had a nine-session group cessation program. Also, type of costs included varied by study, as do resource requirements for similar interventions in different contexts. Changes in the cost per outcome ratio can generally be predicted from changes in the type of costs included in the analysis or changes in the effectiveness of the intervention. The more complex or intensive an intervention, the larger the amount of resources used. The more comprehensive the list of resources, the higher the cost per outcome ratio. The higher the proportion of labor costs or the higher the level of skill of the personnel involved, the more costly the intervention. The more effective the intervention, the lower the cost per outcome achieved even if the program is more expensive. Furthermore, economic evidence was not available for all the interventions.

In spite of the difficulties presented by the limited number of studies, quality limitations, and challenges of standardization, we believe this information will be useful to the Community Guide audience. As the availability and quality of economic data improve, economic information will be increasingly useful for decision-making under budgetary constraints.

### References

1 Gerard K, Mooney G. QALY league tables: handle with care. Health Econ. 1993;2:59-64. [pmid: 8269048].
2 Stone PW, Teutsch SM, Chapman RH, Bell C, Goldie SJ, Neumann PJ. Cost-utility analyses of clinical preventive services: published ratios, 1976-1997. Am J Prev Med. 2000;19:15-23. [pmid: 10865159].
3 Oster G, Huse DM, Delea TE, Colditz GA. Cost-effectiveness of nicotine gum as an adjunct to physician's advice against cigarette smoking. JAMA. 1986;256:1315-8. [pmid: 3091857].