# Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke

Background: This paper presents the results of systematic reviews of effectiveness, applicability, other effects, economic evaluations, and barriers to use of selected population-based interventions intended to reduce tobacco use and exposure to environmental tobacco smoke. The related systematic reviews are linked by a common conceptual approach. These reviews form the basis of recommendations by the Task Force on Community Preventive Services (the Task Force) regarding the use of these selected interventions.

Medical Subject Headings (MeSH): smoking prevention & control; smoking cessation; tobacco use cessation; tobacco smoke pollution; community health services; decision-making; evidence-based medicine; systematic reviews; population-based interventions; practice guidelines; preventive health services; public health practice; task force.

## Introduction

Tobacco use is the largest cause of preventable morbidity and mortality in the United States. ^1, ^ ^2, ^ ^3^ Recognized as a cause of multiple cancers, heart disease, stroke, complications of pregnancy, and chronic obstructive pulmonary disease, ^4^ tobacco use is responsible for 430,000 deaths per year among adults, and direct medical costs are in the range of $50-$73 billion per year. ^5^ ^6^

Exposure of nonsmokers to environmental tobacco smoke (ETS) is another entirely preventable cause of significant morbidity and mortality associated with tobacco use. ^7^ ^8^ ^9^ Exposure to ETS is a recognized cause of heart disease and accounts for an estimated 3,000 lung cancer deaths per year in adults. ^8^ In infants and children, exposure to ETS causes middle ear infections and effusions, exacerbates 400,000-1,000,000 cases of asthma annually, and causes 150,000-300,000 cases of lower respiratory tract infections each year. ^5^ ^7^

Cigarette consumption, the dominant form of tobacco use, peaked in the United States in 1963, and the prevalence of tobacco use among adults in 1964 was 40.3%. ^4^ The beginning of a steady but slow decline in tobacco use by adults followed the release and dissemination of the 1964 report of the advisory committee to the Surgeon General on smoking and health, which summarized more than a decade of research on the adverse health effects of tobacco use. ^10^ The impact of subsequent education and tobacco control efforts (led at various times by government, public and private groups, and individuals) has been considerable, with an estimate of 200,000 premature deaths avoided in the period 1964-1978 alone. ^11^

Despite 36 years of policies, regulations, educational efforts, and increasing information on the negative health effects of tobacco use and the positive health benefits of cessation, tobacco use remains unacceptably high. In 1998, there were 47.2 million adult smokers in the United States. Smoking prevalence among adults aged 18 years and older was 24.1% (men 26.4%; women 22.0%). ^12^ There are regional, educational, socioeconomic, racial, and ethnic variations in tobacco use and disparities in tobacco-related morbidity and mortality. ^4^ ^13^ Individuals below the poverty line, for example, are more likely to smoke than individuals at or above the poverty line (32.3% compared with 23.5%). Persons with 16 or more years of education are less likely to smoke than persons with 9-11 years of education (11.3% compared with 36.8%). ^12^ The prevalence of smoking among American Indians and Alaska natives (40%) is higher than in other racial and ethnic groups. ^12^

Tobacco use results in true drug dependence in most users, making attempts to quit difficult and relapses common. ^14^ Many users make multiple attempts to quit. ^15^ In 1998, an estimated 15.2 million current smokers (39.2%) had stopped smoking for at least one day during the preceeding 12 months because they were trying to stop smoking entirely. ^12^ Although cessation significantly reduces the immediate and subsequent risks of tobacco-related morbidity and mortality, ^3^ ^16^ most tobacco users do not receive assistance in quitting. ^14^

Rather than treating tobacco use cessation as a single event, recent reviews of cessation strategies have stressed recognition of tobacco use as a chronic disease in implementing and maintaining programs to support users in their extended efforts to quit. ^14^ ^15^ Despite knowledge of the health benefits of tobacco use cessation and the availability of effective treatments and therapies, many health care providers and health care systems fail to assess and treat tobacco use consistently and effectively. ^14^

Preventing the acquisition of this costly, chronic dependence is clearly desirable. However, tobacco use initiation and the transition from experimentation to addiction are not easy to prevent because they occur primarily in adolescence, when individuals are more susceptible to influences from family, friends, peers, society, and the tobacco industry, which encourage tobacco use. ^17^ Among high school students in the United States, current smoking prevalence rose significantly between 1991 and 1999, from 27.5% to 34.8%. ^18^ Recent increases in smoking prevalence among young adults aged 18-24 years (27.9% in 1998), in addition to reflecting the aging of the cohort of high school students among whom current smoking rates were high during the 1990s, may also indicate an increase in tobacco use initiation in this segment of the population. ^12^

The health effects of exposure to ETS have prompted the increasing implementation of public and private policies restricting smoking. ^4^ Although ETS exposures in some settings, such as hospitals and transportation systems in the United States, have been reduced or eliminated, nearly 9 of 10 nonsmokers still have some exposure to ETS. ^5^ ETS exposure continues to occur in workplaces and public areas without smoking bans or effective restrictions, and in households in which smoking is allowed.

Interventions to reduce tobacco use and ETS exposure implemented and evaluated over the last 35 years provide considerable evidence on the effectiveness of clinical and community strategies. Given the massive burden of current addiction, premature death and disability, and the implications for the future, efforts to identify, implement, and maintain or expand effective tobacco prevention and control efforts should be a priority at the national, state, local, and individual levels.

## The Guide to Community Preventive Services

The systematic reviews in this report represent the work of the independent, nonfederal Task Force on Community Preventive Services (the Task Force). The Task Force is developing the Guide to Community Preventive Services (the Community Guide ) with the support of the U.S. Department of Health and Human Services (DHHS) in collaboration with public and private partners. CDC provides staff support to the Task Force for development of the Community Guide. A special supplement to the American Journal of Preventive Medicine, "Introducing the Guide to Community Preventive Services: Methods, First Recommendations and Expert Commentary," published in January 2000, presents the background and the methods used in developing the Community Guide.

## Conceptual Approach

The methods used to conduct the systematic reviews and arrive at the evidence-based recommendations contained in this paper are explained in Appendix A. Tables and figures summarizing effectiveness findings and tables that support our economic analyses are available at the website: www.thecommunityguide.org.

An illustration of the logic framework depicts our conceptual approach to the subject of tobacco use prevention and control (Figure 1). This figure portrays the relationships among the population, the key tobacco use behaviors, categories of interventions, and important outcomes. The key prevention and control outcomes depicted in the logic framework are: (1) reducing exposure to environmental tobacco smoke (ETS); (2) reducing tobacco use initiation; and (3) increasing tobacco use cessation. The effectiveness of interventions reviewed in this report is measured by the evidence of an effect on one or more of these categories of outcomes. We also organized the selected interventions based on these categories.

Figure 1. Logic framework depicting the conceptual approach used in these reviews

As indicated in the logic framework, these outcomes are not independent. Increasing tobacco use cessation, for example, will also reduce exposure to ETS. Conversely, efforts to reduce exposure to ETS may increase tobacco use cessation. The interactions illustrate the potential for synergistic progress in reducing tobacco use and ETS exposure.

We focused on interventions intended to achieve tobacco use prevention and control in the general population, which includes tobacco product users, persons at risk for tobacco product use, and persons exposed or at risk of exposure to ETS. With one exception, we did not evaluate interventions that targeted only high-risk persons (e.g., cessation interventions for smokers with coronary artery disease, cessation programs conducted entirely in hospital settings, or interventions to reduce ETS exposure in homes with asthmatic children), and studies conducted in these populations were not considered in the body of evidence upon which the Task Force based its evaluations. Studies evaluating health-care system and community interventions to reduce tobacco use among populations of pregnant women were included in this review.

This review did not examine the evidence of effectiveness of clinical cessation programs (including provider counseling) or therapies for tobacco use and dependence. In general, the Community Guide does not review clinical interventions (i.e., interventions provided face-to-face by individual health care providers to individual clients in clinical settings), although it does review population-based interventions to increase the use of effective clinical interventions in communities and health care systems. Based on these criteria, we did examine the evidence of effectiveness of interventions implemented to increase patient use of effective tobacco use treatments, and interventions to increase provider delivery of effective treatments and therapies to their patients. The evaluations in the Community Guide complement the recently updated Clinical Practice Guideline: Treating Tobacco Use and Dependence, ^14^ which provides an extensive, evidence-based review of both provider and health care system strategies for helping patients to quit. Taken together, these reviews present a range of options for increasing and improving patient tobacco use cessation. (See also, "Evidence Reviews and Recommendations on Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke: A Summary of Selected Guidelines,")

In selecting the interventions evaluated in this report, we first generated a comprehensive list of interventions (a total of 92 interventions in 20 categories). Time and resource constraints prohibited our evaluating all of the identified interventions (the comprehensive list included, for example, community-wide risk factor screening and counseling, worksite-specific smoking cessation programs, and patient cessation support conducted by mail). Interventions were selected for review by a team of tobacco prevention and control expert consultants,* based on their professional judgment and subjective assessment of the degree of importance and perceived extent of practice. Selected interventions were identified by: (1) the nature and components of the activities involved; (2) the manner of delivery of the activities; (3) the target population (e.g., general populations, groups of tobacco product users, patients, and health care providers); and (4) the setting in which the intervention was applied (e.g., health care setting, local area, state, or nation).

We reviewed interventions that were either single-component (using only one activity), or multicomponent (using more than one activity together) to achieve desired outcomes. We assessed the effectiveness of multicomponent interventions in improving the outcomes of interest whether or not the relative contribution of individual components could be ascribed. For several interventions reviewed in this report, most or all of the studies evaluated described multicomponent strategies. An effort was made to distinguish between an intervention when implemented alone and when implemented as part of a multicomponent strategy. As noted above, in some cases this was not possible.

We grouped studies together on the basis of their similarity. Sometimes we found that our classification or nomenclature was different from that used in the original studies being reviewed. To achieve comparability in the review process, we grouped such studies according to our definitions of the interventions.

This report contains evidence reviews of 14 interventions organized into three sections: (1) strategies to reduce exposure to environmental tobacco smoke; (2) strategies to reduce tobacco use initiation; and (3) strategies to increase tobacco use cessation. Reviews for three additional interventions (restricting youth access to tobacco products, school-based education, and tobacco industry and product restrictions) are still in progress; these evaluations will be published once they are completed (the expected completion date is Spring 2001).

## Healthy People 2010 Goals and Objectives

The interventions reviewed in this paper can be useful in reaching many of the tobacco control objectives in Healthy People 2010, ^19^ a prevention agenda for the United States. These objectives identify the significant preventable threats to health and focus public and private sector efforts for addressing those threats. Many of the proposed Healthy People objectives in chapter 27, "Tobacco Use," relate directly to goals for increasing cessation, reducing initiation, and reducing exposure to environmental tobacco smoke (Table 1). This paper, in combination with the accompanying recommendations, provides information on interventions that can help communities and health care systems reach Healthy People 2010 objectives.

Table 1. Selected Healthy People 2010 objectives related to tobacco use and ETS exposure

Tobacco Use in Population Groups
27-1 | Adult tobacco use: Reduce cigarette smoking prevalence from 24% to 12%
27-2 | Adolescent tobacco use: Reduce tobacco use (past month) from 43% to 21%
27-3 | Reduce initiation of tobacco use among children and adolescents (developmental)
27-4 | Age at first tobacco use: Increase (delay) the average age of first tobacco use from 12 yrs to 14 yrs
Cessation and Treatment
27-5 | Smoking cessation by adults. Increase the percentage of adult smokers stopping smoking for a day or longer from 43% to 75%
27-6 | Smoking cessation during pregnancy: Increase smoking cessation in pregnant women in the first trimester of pregnancy from 12% to 30%
27-7 | Smoking cessation by adolescents: Increase the percentage of adolescent ever-daily smokers who try to quit from 73% to 84%
27-8 | Insurance coverage of cessation treatment: Increase total coverage of FDA-approved pharmacotherapies and behavioral therapies in: Managed care organizations-from 75% to 100% Medicaid programs in states and the District of Columbia-from 24 states to 51 states
Exposure to Secondhand Smoke (ETS)
27-9 | Exposure to tobacco smoke at home among children: Reduce the proportion of children who are regularly exposed to tobacco smoke at home from 27% to 10%
27-10 | Exposure to environmental tobacco smoke: Reduce the proportion of nonsmokers exposed to ETS from 65% to 45%
27-11 | Smoke-free and tobacco-free schools: Increase the proportion of smoke-free and tobacco-free middle, junior high, and senior high schools from 37% to 100%
27-12 | Worksite smoking policies: Increase the proportion of worksites with formal smoking policies that prohibit smoking or limit it to separately ventilated areas from 79% to 100%
27-13 | Smoke-free indoor air laws: Establish smoke-free indoor air laws that prohibit smoking or limit it to separately ventilated areas in public places and worksites in every state and the District of Columbia (for a total of 51 states). Baseline data, 1998, shows the number of states with laws in effect as follows: Private workplaces-1; Public workplaces-13; Restaurants-3; Public transportation-16; Day care centers-22; Retail stores-4
Social and Environmental Changes
27-14 | Enforcement of laws prohibiting the sale of tobacco products to minors: Increase from 0 to 51 the number of states (including the District of Columbia) preventing the sale of tobacco products to minors (an illegal purchase rate of 5% or less for minors)
27-15 | Retail license suspension for sales to minors:Increase from 34 to 51 the number of States (including the District of Columbia) that suspend or revoke state licenses for violation of laws prohibiting the sale of tobacco to minors
27-16 | Eliminate tobacco advertising and promotion targeting adolescents and young adults (developmental)
27-17 | Adolescent disapproval of smoking: Increase the proportion of adolescents who disapprove of smoking from 80% to 95% of 8^th^ grade students; from 75% to 95% of 10^th^ grade students; and from 69% to 95% of 12^th^ grade students
27-18 | Tobacco control programs: Increase the number of tribes, territories, states, and the District of Columbia with comprehensive, evidence-based tobacco control programs (developmental)
27-19 | Preemptive tobacco control laws: Reduce the number of states that have laws that preempt stronger tobacco control laws from 30 to 0
27-20 | Tobacco product regulation: Establish a regulatory structure to monitor toxicity (developmental)
27-21 | Tobacco tax: Increase the average Federal and State tax on tobacco products. Increase the average tax on cigarettes from $0.63 to $2 per pack.Increase the average tax on spit tobacco from $0.27 to $2 per unit

## Part I: Strategies to Reduce Exposure to Environmental Tobacco Smoke

Interventions to reduce exposure to environmental tobacco smoke (ETS) require or encourage the establishment of smoke-free areas in workplaces, in public areas, and in the home. Smoke-free workplaces, public areas, and homes can be effective in reducing tobacco-related morbidity and mortality in several ways. First, these policies can reduce exposure to environmental tobacco smoke, contributing to a reduction in ETS-related morbidity and mortality. ^7^ ^8^ ^9^ Second, smoke-free policies could change attitudes and behaviors of smokers and increase both the number of persons who attempt to quit and the number of attempts per person. By reducing opportunities for relapse, smoke-free policies might also improve the success rate for each quit attempt. ^20^ Third, smoke-free policies challenge the perception of smoking as a normative adult behavior. ^21^ By changing this perception, these policies could change the attitudes and behaviors of adolescents, resulting in a reduction in tobacco use initiation. ^22^ Increasing the number of smokers who quit and/or reducing the number of new users will result in fewer tobacco users and a reduction in tobacco-related morbidity and mortality (and further reduce exposure to ETS). ^3^

This section covers evaluations of the evidence of effectiveness of two interventions to reduce exposure to ETS. The interventions reviewed are smoking bans and restrictions to address exposure in the workplace and in public areas, and community education to reduce exposure to ETS, especially among children, in the home environment.

### Smoking Bans and Restrictions

#### Definition

Smoking bans and restrictions are private, nongovernment, and government policies, regulations, and laws that limit smoking in workplaces and public areas. Smoking bans entirely prohibit smoking in geographically defined areas; smoking restrictions limit smoking to designated areas. Smoking bans and restrictions can be implemented with additional interventions, such as education and tobacco use treatment programs.

#### Background

Businesses establish smoking policies to protect employees and customers from exposure to ETS in the workplace. Accrediting agencies set regulations to protect employees and patrons within their organizations (e.g., Joint Commission on Accreditation of Healthcare Organizations). Federal, state, or local laws are implemented to protect persons from ETS exposure in public areas, and to establish minimum standards for both public and private workplaces. For regulations and laws establishing smoking restrictions, standards often include the size, location, and ventilation requirements for designated smoking areas.

#### Review of evidence: effectiveness

Our search identified a total of 54 studies regarding the effectiveness of smoking bans or restrictions. ^23, ^ ^24, ^ ^25, ^ ^26, ^ ^27, ^ ^28, ^ ^29, ^ ^30, ^ ^31, ^ ^32, ^ ^33, ^ ^34, ^ ^35, ^ ^36, ^ ^37, ^ ^38, ^ ^39, ^ ^40, ^ ^41, ^ ^42, ^ ^43, ^ ^44, ^ ^45, ^ ^46, ^ ^47, ^ ^48, ^ ^49, ^ ^50, ^ ^51, ^ ^52, ^ ^53, ^ ^54, ^ ^55, ^ ^56, ^ ^57, ^ ^58, ^ ^59, ^ ^60, ^ ^61, ^ ^62, ^ ^63, ^ ^64, ^ ^65, ^ ^66, ^ ^67, ^ ^68, ^ ^69, ^ ^70, ^ ^71, ^ ^72, ^ ^73, ^ ^74, ^ ^75, ^ ^76^ Of these, 17 studies evaluated the impact of the intervention on exposure to environmental tobacco smoke. ^23, ^ ^27, ^ ^28, ^ ^30, ^ ^31, ^ ^35, ^ ^36, ^ ^38, ^ ^40, ^ ^42, ^ ^47, ^ ^48, ^ ^53, ^ ^55, ^ ^57, ^ ^61, ^ ^72^ Thirty-nine studies evaluated only the effect of smoking bans and restrictions on tobacco use behaviors, and these studies are considered below. Five papers provided additional information regarding an already-included study. ^77, ^ ^78, ^ ^79, ^ ^80, ^ ^81^ Seven of the 17 studies were not included in the review of effectiveness because of least suitable study designs and fair or limited execution quality. ^23, ^ ^27, ^ ^30, ^ ^38, ^ ^40, ^ ^48, ^ ^53^ Details of the 10 qualifying studies ^28, ^ ^31, ^ ^35, ^ ^36, ^ ^42, ^ ^47, ^ ^55, ^ ^57, ^ ^61, ^ ^72^ are provided in Appendix B-1, and at the website: www.thecommunityguide.org.

The 10 qualifying studies provided a total of 12 measurements of the impact of smoking bans and restrictions on exposure to environmental tobacco smoke (Figure 2). Overall, 9 of the 10 studies ^28, ^ ^31, ^ ^35, ^ ^36, ^ ^47, ^ ^55, ^ ^57, ^ ^61, ^ ^72^ observed reductions or differences in ETS exposure in workplaces that had smoking bans or restrictions. In four studies, environmental measurements of components of ETS (such as nicotine vapor) were collected before and after implementation of the smoking ban or restriction. ^28, ^ ^35, ^ ^55, ^ ^72, ^ Environmental measurements of ETS components decreased by a median relative percentage difference of -72% (range -44% to -97%) in assessments conducted between 6 months and 12 months after implementation of the ban or restriction. Six studies provided a total of 8 measurements of differences in self-reported exposure to ETS. ^31, ^ ^36, ^ ^42, ^ ^47, ^ ^57, ^ ^61^ In assessments conducted between 4 and 18 months post-implementation, the median relative percentage difference in self-reported ETS exposure was -60% (range of +4% to -94%).

Figure 2. Relative percentage changes in exposure to environmental tobacco smoke attributable to workplace smoking bans and restrictions from studies that qualified for inclusion in this review

Four studies evaluated the impact of smoking restrictions, ^36, ^ ^42, ^ ^47, ^ ^55^ four studies measured the impact of smoking bans, ^28, ^ ^35, ^ ^57, ^ ^72^ and two studies measured differences in workplace ETS exposure for both. ^31, ^ ^61^ In general, reductions in ETS exposure were greater in workplaces that had smoking bans than in those with only smoking restrictions (Figure 2).

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of smoking bans and restrictions to different settings and populations. Smoking bans and restrictions were evaluated in a variety of settings including hospitals and medical centers, ^28, ^ ^57, ^ ^72^ health care provider offices, ^57^ government or public sector workplaces, ^35, ^ ^47, ^ ^55^ and a university. ^42^ Studies on representative samples of employed persons in California, ^31, ^ ^61, ^ ^79, ^ ^80^ and in Missouri ^36^ demonstrated that smoking bans and restrictions reduced self-reported ETS exposure in workplaces community-wide. Studies included representative samples of indoor workers in the states of California ^31, ^ ^61, ^ ^79, ^ ^80^ and Missouri, ^36^ and large, diverse samples of government employees in Texas ^47^ and HMO employees in Oregon. ^57^ The evidence of effectiveness in these studies should extend to most indoor workers in the United States.

In 4 studies, smoking bans or restrictions were implemented and evaluated in response to a government law. ^35, ^ ^36, ^ ^47, ^ ^55^ In 4 studies the bans or restrictions were the result of private-sector policies. ^28, ^ ^42, ^ ^57, ^ ^72^ Two studies measured the effect of smoking bans or restrictions created through workplace policies or local ordinances. ^31, ^ ^61^

No studies were found that evaluated the effect of smoking bans or restrictions in public settings outside of the workplace, such as public transportation systems or sports and entertainment venues.

#### Review of evidence: other positive or negative effects

Fifty of the 54 studies in the body of evidence measured the effectiveness of smoking bans or restrictions on one or more tobacco use behaviors, including consumption (cigarettes per shift or per day), cessation attempts, cessation, or smoking prevalence. ^24, ^ ^25, ^ ^26, ^ ^27, ^ ^28, ^ ^29, ^ ^30, ^ ^32, ^ ^33, ^ ^34, ^ ^35, ^ ^37, ^ ^38, ^ ^39, ^ ^40, ^ ^41, ^ ^42, ^ ^43, ^ ^44, ^ ^45, ^ ^46, ^ ^47, ^ ^49, ^ ^50, ^ ^51, ^ ^52, ^ ^54, ^ ^55, ^ ^56, ^ ^57, ^ ^58, ^ ^59, ^ ^60, ^ ^62, ^ ^63, ^ ^64, ^ ^65, ^ ^66, ^ ^67, ^ ^68, ^ ^69, ^ ^70, ^ ^71, ^ ^72, ^ ^73, ^ ^74, ^ ^75, ^ ^76, ^ ^77, ^ ^80^ However, 41 of these studies ^24, ^ ^25, ^ ^26, ^ ^27, ^ ^28, ^ ^30, ^ ^32, ^ ^33, ^ ^35, ^ ^37, ^ ^38, ^ ^39, ^ ^40, ^ ^41, ^ ^43, ^ ^44, ^ ^45, ^ ^46, ^ ^49, ^ ^51, ^ ^54, ^ ^55, ^ ^56, ^ ^58, ^ ^59, ^ ^60, ^ ^63, ^ ^64, ^ ^65, ^ ^66, ^ ^67, ^ ^68, ^ ^69, ^ ^71, ^ ^72, ^ ^73, ^ ^74, ^ ^75, ^ ^76, ^ ^77, ^ ^80^ were not included in the review of effectiveness because of least suitable study designs. Details of the 9 qualifying studies ^29, ^ ^34, ^ ^42, ^ ^47, ^ ^50, ^ ^52, ^ ^57, ^ ^62, ^ ^70^ are provided in Appendix B-2, and at the website: www.thecommunityguide.org.

All 9 qualifying studies measured self-reported cigarette consumption, and 8 of the 9 studies ^29, ^ ^34, ^ ^42, ^ ^47, ^ ^50, ^ ^52, ^ ^62, ^ ^70^ observed either reductions or lower levels of reported cigarette consumption in the group or population exposed to smoking bans or restrictions. Overall, the median absolute change was -1.2 cigarettes per day (range: no change in consumption to -4.3 cigarettes per day) with follow-up periods of up to 2 years.

Four studies of smoking bans ^34, ^ ^52, ^ ^62, ^ ^70^ measured self-reported smoking cessation in sampled smokers over follow-up periods of 4 weeks to 18 months. In one small study, ^34^ none of the smokers quit in the 4 weeks of follow-up. In each of 3 studies with study periods of 12-18 months, ^52, ^ ^62, ^ ^70^ a larger proportion of smokers subject to a workplace smoking ban quit compared with smokers subject to lesser or no workplace smoking restrictions. In 2 of these studies, ^62, ^ ^70^ the absolute percentage changes were +7.9 and +9.6 percentage points, respectively. The third study ^52^ reported an adjusted relative risk of 1.7 (95% CI 1.2, 2.4).

Six studies ^29, ^ ^42, ^ ^47, ^ ^50, ^ ^57, ^ ^62^ measured changes or differences in tobacco use prevalence. Three studies ^29, ^ ^47, ^ ^62^ observed reductions in prevalence following implementation or exposure to smoking bans or restrictions (absolute percentage changes of -1.4, -3.4, and -11.4 percentage points). Three studies ^42, ^ ^50, ^ ^57^ observed small increases in tobacco use prevalence (absolute percentage changes of +0.4, +0.8, +1.0 percentage points).

This body of evidence led the Task Force to the conclusion that smoking restrictions and bans appear to have an effect on tobacco consumption and cessation, but the evidence of an effect on tobacco use prevalence is less consistent.

Additional benefits of smoking bans or restrictions include reduced workplace cleaning costs and reduced risk for fires. ^82^ Seven papers describing six studies provided evidence that smoking ordinances do not have an adverse economic effect on businesses (including bars and restaurants) or on tourism. ^83, ^ ^84, ^ ^85, ^ ^86, ^ ^87, ^ ^88, ^ ^89^

#### Review of evidence: economic

One study conducted in the United States modeled the costs and benefits of a proposed national smoke-free environment act to restrict or ban smoking inside all non-residential buildings regularly entered by 10 or more persons per week. ^82^ Costs included implementation of the restriction or ban by the establishment, construction, and maintenance of smoking lounges, and enforcement. Benefits included savings on medical costs by averting heart disease, value of lives saved obtained by willingness-to-pay methods, costs averted by reduced smoking-related fires, and productivity improvements. The net present benefit to society adjusted to the Community Guide reference case was in the range of $42 to $78 billion. This range was based on high and low estimates of benefits and costs. This study was classified as very good, based on the criteria for quality assessment of economic data used in the Community Guide. ^90^ (See also Appendix C, Interpreting the Economic Data.)

#### Barriers to intervention implementation

A major barrier to efforts by local governments to adopt smoking bans is preemption, which is the passage or presence of a state law with weaker smoking restrictions that prevents implementation and enforcement of stronger local laws. ^91^ ^92^ Eliminating preemption statutes is one of the tobacco objectives of Healthy People 2010. ^19^ Another major barrier to the adoption of local, state, and national smoking bans is political opposition by smokers, businesses concerned about potential changes in revenue, and tobacco industry-sponsored groups. ^93^

#### Conclusion

According to the Community Guide's rules of evidence, there is strong scientific evidence that smoking bans and restrictions reduce exposure to environmental tobacco smoke in the workplace.

### Community Education to Reduce Exposure to Environmental Tobacco Smoke in the Home

#### Definition

Community education includes all efforts to increase knowledge and to change attitudes about the health effects of exposure to environmental tobacco smoke. Techniques include mass media messages, small media messages (including educational materials), and counseling provided outside of health care settings.

#### Background

Community education provides information to parents, other occupants, and visitors to the home about the health risks of ETS for nonsmoking adults and for children. For infants and children, most ETS exposure occurs in the home. ^94^ Information could change the knowledge and attitudes of smokers, prompting them to reduce or eliminate smoking indoors, reduce consumption, or quit entirely. Non-smokers might increase their support and encouragement to smoking household members to quit, or create and enforce home smoking bans or restrictions. The combination of reduced indoor smoking and increased cessation would result in a reduction in indoor ETS exposure, with a consequent reduction in morbidity and mortality.

#### Review of evidence: effectiveness

Our search identified a total of 3 studies that evaluated effectiveness of education in the adoption of home smoking policies, in reducing ETS exposure in the home, or in changing tobacco use behaviors. ^44, ^ ^95, ^ ^96^ Two studies were excluded because of limitations in execution, ^96^ or a least suitable study design. ^44^ Details of the qualifying study ^95^ are available at the website: www.thecommunityguide.org.

The single qualifying study evaluated a randomized trial of home nurse visits to assist families in reducing infant exposure to ETS. The nurse visits provided a variety of home education aids and an opportunity to discuss options for home smoking policies. At a 12-month follow-up the absolute percentage difference in reported infant exposure to ETS was -4 percentage points (relative decrease of 12%). However, households in the intervention group reported an increase in infant exposure to ETS over the period of the study, from 33% at baseline to 49% at 12-month follow-up.

#### Review of evidence: applicability

The only qualifying study evaluated home nurse visits to families in central North Carolina. ^95^

#### Review of evidence: other positive or negative effects

Potential benefits of education to reduce ETS exposure in the home include changes in tobacco use behaviors such as an increase in cessation attempts and successful cessation. No harms of community education to reduce ETS exposure in the home were identified in the literature or by the chapter development team.

#### Review of evidence: economic

Economic evaluation information was not reviewed because there was insufficient evidence of effectiveness of the intervention.

#### Barriers to intervention implementation

No barriers were identified to the implementation of community education strategies focused on reducing ETS exposure in the home.

#### Conclusion

According to the Community Guide's rules of evidence, the evidence of effectiveness of education strategies in reducing exposure to ETS in the home environment is insufficient because of the small number of available studies and limitations in the design and execution of available studies.

### Research Issues for Reducing Exposure to Environmental Tobacco Smoke

#### Effectiveness

The effectiveness of smoking bans and restrictions in reducing exposure to environmental tobacco smoke in the workplace is established. Research issues, which have been identified by others, ^20^ overlap with questions generated as a result of this review.

- What are the relative effects of smoking bans and restrictions on tobacco use behaviors? What is the full range of effects on tobacco use behaviors that occurs in response to smoking bans and to smoking restrictions? In addition to reducing exposure to ETS, what are the effects on tobacco use cessation and tobacco use prevalence?
- What are the extended effects (beyond 1-2 years post implementation) of smoking bans and restrictions on the tobacco use behaviors of workers? Do these effects increase over time?
- What is the full range of effects that occurs in communities in response to different types of local ordinances?
- How does the effectiveness of smoking policies vary by the specific requirements of the legislation and vigorousness of enforcement?
- How is the impact of workplace smoking policies affected by the size and composition of the workforce?
- What is the full range of health benefits that results from reducing or eliminating exposure to ETS in workers and customers currently exposed to ETS on a regular basis (e.g., in restaurants, bars, and casinos)?
- How do cultural characteristics of businesses and workers contribute to increased or decreased effectiveness of smoking bans and restrictions?

The effectiveness of community education interventions in reducing exposure to ETS in the home has not been established. Basic research questions proposed by others ^94, ^ ^97^ overlap the questions generated from this review.

- How effective are educational methods in reducing exposure to ETS in the home?
- What are the relative contributions to reducing home ETS exposures of (1) adherence to policies that ban or restrict smoking in the home? and (2) smoking cessation?
- Do policies in the home that ban or restrict smoking reduce exposure to ETS? In adults? In children? Are households with children more likely to adopt policies that ban or restrict smoking in the home?
- Are home smoking bans more effective than smoking restrictions?
- What information or message is effective in prompting and maintaining practices in the home?
- What channels are effective for dissemination of information to reduce home ETS?

#### Applicability

Workplace smoking bans and restrictions should be applicable in most workplace settings and populations. However, possible differences in the effectiveness of each intervention for specific subgroups of the population could not be determined. Several questions regarding applicability of these interventions in settings and populations other than those studied remain.

- Are smoking bans effective in high schools in reducing exposure to ETS and/or tobacco use?
- Are smoking bans and restrictions effective in universities in reducing exposure to ETS and/or tobacco use?
- Are smoking bans effective in child care settings in reducing exposure to ETS?
- Do meaningful differences exist in effectiveness of smoking bans and restrictions based on the level or scale of implementation (private, local, state, national)?

#### Other positive or negative effects

Smoking bans and restrictions may have important effects on such tobacco use behaviors as consumption, cessation attempts, and cessation. Assessing the full range of effects of smoking bans and restrictions is important and was addressed above under "Effectiveness." In addition, research on the following issues would be useful:

- How effective are workplace smoking bans and restrictions in reducing relapses?
- Do smoking bans and restrictions divert tobacco consumption from cigarettes to smokeless tobacco?
- To what extent, if any, do workplace smoking bans and restrictions increase consumption and ETS exposures in the home?
- What effects do workplace smoking bans and restrictions have on productivity?

#### Economic evaluations

The available economic information consisted of a single evaluation. Considerable research is therefore warranted regarding the following questions:

- What are the costs of these interventions?
- What is the cost-effectiveness, net cost, or net benefit of smoking bans and restrictions when the cost-effectiveness analysis includes cost of illness averted?

#### Barriers

Research issues important to communities and local governments identified in this evaluation include:

- What aspects of efforts to prevent or to overturn state preemption laws are effective?
- What aspects of efforts to pass local smoking bans are effective in addressing local concerns and industry-organized opposition? What arguments for smoking bans are most persuasive to voters? To local legislative bodies?

Published reports of community and state efforts to pass smoking bans in California are informative, ^93^ and continued investigation is warranted to identify and to disseminate information to counter the evolving strategies of the tobacco industry.

## Part II. Strategies to Reduce Tobacco Use Initiation

Interventions that reduce tobacco use initiation are designed to change knowledge, attitudes, and tobacco use behaviors in children, adolescents, and young adults. Most smokers initiate tobacco use during adolescence, and nicotine addiction begins during the first few years of use. ^98^ Major risk factors for tobacco initiation among children and adolescents are perceptions that tobacco use is a common and normative peer and adult behavior, and the availability and accessibility of tobacco products. ^17^ Preventing or delaying experimentation with tobacco products or preventing the transition from experimentation to regular use and tobacco dependence are the major goals of interventions reviewed in this section. Two interventions are evaluated in this section: increasing the unit price for tobacco products, and mass media campaigns.

### Increasing the Unit Price for Tobacco Products

#### Definition

Interventions to increase the unit price for tobacco products include legislation at the state or national level to raise the product excise tax. Although other factors affect tobacco product pricing, excise tax increases have historically resulted in an equivalent or larger increase in tobacco product price. ^99^

#### Background

Excise taxes on tobacco products make the use of tobacco products less attractive to adolescents and young adults who have limited resources and a variety of options for spending available money. Excise tax increases have primarily occurred in individual states, as most attempts at the federal level have been unsuccessful. State excise tax increases have occurred as a result of legislative action, and in some states as a result of statewide referendum. Referenda passed in California, Massachusetts, Oregon, and Arizona provided various proportions of excise tax funds by mandate or recommendation to support statewide education programs and mass media campaigns. ^100^

#### Review of evidence: effectiveness

Our search identified 8 studies regarding the effectiveness of increasing the price of tobacco products on changing the tobacco use behaviors of adolescents and/or young adults. ^101^ ^102^ ^103^ ^104^ ^105^ ^106^ ^107^ ^108^ Three additional papers provided more information on an already-included study. ^109^ ^110^ ^111^ All of the studies were conducted in the United States. Five studies examined the effect of product price on tobacco use in adolescents (13-18 years), ^103^ ^104^ ^105^ ^106^ ^108^ and three studies examined the effect of product price on tobacco use in young adults (18-24 years, or < 25 years). ^101^ ^102^ ^107^ All of the identified studies were of moderate or greatest suitability of study design and fair or good quality of execution. Details of these 8 qualifying studies are provided at the website: www.thecommunityguide.org.

All eight studies employed econometric methods in analysis of single or sequential cross-sectional surveys of populations of students and/or young adults. Local tobacco product price and price changes or differences over the period of study were combined with the survey responses on tobacco use and consumption to calculate price elasticity of demand estimates (the percentage change in quantity demanded resulting from a 1% change in price). Price elasticity of demand estimates provided in these studies included participation (i.e., tobacco use prevalence), tobacco product consumption (such as cigarettes smoked per day), and an overall estimate (participation and consumption). A negative price elasticity of demand estimate reflects a decrease in tobacco use in response to an increase in tobacco product price. All of the studies attempted to control for concurrent tobacco prevention and control efforts including differences in smoking restrictions, youth tobacco access laws, school tobacco education programs, and exposure to anti-tobacco media.

The study periods differed for each qualifying study, with some overlap. Five studies evaluated the effect of price on tobacco use for study periods that included the 1990s, ^101^ ^102^ ^103^ ^104^ ^106^ while three studies reported the effect of price on tobacco use for periods before 1990. ^105^ ^107^ ^108^

Price elasticity of demand estimates from seven studies ^101^ ^102^ ^103^ ^104^ ^105^ ^106^ ^107^ demonstrated that higher tobacco product prices are associated with lower levels of tobacco use by adolescents and young adults. One study ^108^ did not find a statistically significant effect of price on adolescent tobacco use, after controlling for such tobacco use regulations as smoking restrictions. For tobacco use prevalence, the price elasticity estimates ranged from "no statistically significant effect" to -1.19 with a median of -0.37 (suggesting that a 10% increase in product price would result in a 3.7% decrease in the prevalence of tobacco use among adolescents). For tobacco consumption (6 studies provided measurements), the price elasticity estimates ranged from 0 to -0.68 with a median of -0.23 (suggesting that a 10% increase in product price would result in 2.3% decrease in the quantity of product consumed by adolescent users).

The subset of five studies conducted on surveys from adolescents (13-18 years) ^103^ ^104^ ^105^ ^106^ ^108^ determined price elasticity of demand estimates for participation (prevalence) that ranged from "no statistically significant effect" to -1.19 with a median of -0.38. Four of these studies also reported estimates for tobacco consumption, ranging from 0 to -0.47 with a median of -0.27.

In the subset of three studies evaluating populations of young adults (18-24 years), ^101^ ^102^ ^107^ the price elasticity measurements were similar to those observed in studies on adolescents. Price elasticity of demand for tobacco use participation ranged from -0.07 to -0.52 with a median of -0.37. For the effect on consumption, two studies reported estimates of of -0.21 and -0.68.

Overall, the price elasticity of demand estimates in 7 of 8 studies demonstrate that increases in tobacco product price result in decreases in both the overall prevalence of tobacco product use and the quantity consumed. Increases in product price resulted in reductions in tobacco use in both adolescents and in young adults.

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different tobacco products, settings, and populations. All of the qualifying studies measured differences in tobacco product price across jurisdictions such as states. Differences in tobacco product prices included, but were not limited to, differences in state excise taxes.

Studies have evaluated the effect of product price on use and consumption of cigarettes ^101^ ^102^ ^103^ ^104^ ^105^ ^106^ ^107^ ^108^ and of smokeless tobacco products. ^107^ ^110^

All of the studies were conducted in the United States and most of the studies used national datasets. The study samples are representative of populations of adolescents and young adults. In addition, some studies reported stratified analyses, demonstrating evidence of effectiveness of price on tobacco use and consumption among whites, ^101^ ^103^ ^104^ blacks, ^101^ ^103^ and Hispanics. ^101^ Two studies observed that both black adolescents and young adults were more responsive to differences in product price than were white adolescents and young adults, respectively. ^101^ ^103^ Studies providing analysis by gender found that tobacco product price increases had a greater effect among males than among females. ^101^ ^103^ ^104^ ^106^

Studies conducted on nationally representative population samples suggest that the evidence of effectiveness should apply to most adolescents and young adults in the United States.

#### Review of evidence: other positive or negative effects

Increases in the price of tobacco products also reduce tobacco use in adults. A review of this body of evidence and additional positive and negative effects are presented in "Part III: Strategies to Increase Tobacco Use Cessation." No information about other positive or negative effects, relevant to reducing initiation in adolescents, was identified.

#### Review of evidence: economic

Econometric analyses were used to evaluate the effectiveness of this economic intervention. The results are reported above in the section, "Review of evidence: effectiveness."

#### Barriers to intervention implementation

Excise tax increases require passage of legislation or statewide referendum. Political opposition is well organized and funded at both the federal and state levels. Published reports provide information on the components and experiences of both successful and unsuccessful state initiatives that proposed an excise tax increase on tobacco products. ^100^ ^112^ ^113^

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence demonstrates the effectiveness of increasing the price of tobacco products on reducing tobacco use prevalence and consumption among both adolescents and young adults.

### Mass Media Campaigns

#### Definition

Campaigns are mass media interventions of an extended duration, using brief, recurring messages to inform and motivate individuals to remain tobacco-free. Message content is developed through formative research, and message dissemination includes the use of paid broadcast time and print space, donated time and space (as public service announcements), or a combination of paid and donated time and print space. Mass media campaigns can be combined with other interventions, such as tobacco product excise tax increases, school-based education, or other community programs.

#### Background

Mass media techniques primarily include broadcast messages on television and radio, although other formats such as billboards, print media, and movies have been used. Campaigns can focus on messages targeting children and adolescents or can include such messages as part of an overall anti-tobacco effort (e.g., including messages targeting tobacco users to increase cessation and messages about reducing exposure to ETS). The content of mass media campaigns designed to educate and motivate children and adolescents to remain tobacco-free can vary, but a recent review identified two primary strategies: agenda setting and demand reduction education. ^114^ Agenda-setting messages increase awareness of strategies used by the tobacco industry to promote tobacco use, and attempt to facilitate changes in both tobacco use behaviors and public policies concerning tobacco. Demand reduction education messages provide information and support to young people to help individuals decide to remain tobacco-free.

#### Review of evidence: effectiveness

Our search identified 14 studies regarding the effectiveness of mass media campaigns in reducing tobacco use in adolescents. ^115, ^ ^116, ^ ^117, ^ ^118, ^ ^119, ^ ^120, ^ ^121, ^ ^122, ^ ^123, ^ ^124, ^ ^125, ^ ^126, ^ ^127, ^ ^128^ Two studies were excluded from the analysis of effectiveness because of least suitable study designs. ^123^ ^126^ Details regarding the 12 qualifying studies are provided at the website: www.thecommunityguide.org. Twenty-eight papers provided additional information on an already-included study. ^129, ^ ^130, ^ ^131, ^ ^132, ^ ^133, ^ ^134, ^ ^135, ^ ^136, ^ ^137, ^ ^138, ^ ^139, ^ ^140, ^ ^141, ^ ^142, ^ ^143, ^ ^144, ^ ^145, ^ ^146, ^ ^147, ^ ^148, ^ ^149, ^ ^150, ^ ^151, ^ ^152, ^ ^153, ^ ^154, ^ ^155, ^ ^156^

The qualifying studies evaluated a variety of mass media campaigns. Nine studies evaluated interventions in which the mass media component focused on youth. ^115, ^ ^116, ^ ^117, ^ ^118, ^ ^119, ^ ^120, ^ ^121, ^ ^122, ^ ^124^ In three studies, the mass media effort included youth-targeted messages within a larger anti-tobacco campaign. ^125, ^ ^127, ^ ^128^ Only one study employed mass media alone (through a variety of outlets). ^120^ In 11 studies, the mass media campaign occurred in coordination or concurrently with other interventions including contests, ^115, ^ ^122^ school-based education programs, ^116, ^ ^117, ^ ^118, ^ ^119, ^ ^121, ^ ^122, ^ ^124, ^ ^125, ^ ^128^ and community education programs. ^116, ^ ^121, ^ ^124, ^ ^125, ^ ^127, ^ ^128^ Two studies were conducted in settings with recognized excise tax increases on tobacco products. ^124, ^ ^127^

The duration of the intervention differed significantly among the studies. Two of the mass media efforts were less than 3 weeks in duration, ^117, ^ ^118^ three interventions were less than two years in duration, ^115, ^ ^121, ^ ^122^ and seven campaigns were two or more years in duration. ^119, ^ ^120, ^ ^124, ^ ^125, ^ ^127, ^ ^128, ^ ^133^

The 12 qualifying studies provided 12 measurements of tobacco use. Five studies reported differences in rates of self-reported tobacco use between intervention and comparison groups. ^115, ^ ^116, ^ ^122, ^ ^124, ^ ^125, ^ In follow-up periods that ranged from 2 to 5 years, the reported absolute percentage differences ranged from +0.02 to -9.5 percentage points with a median of -2.4 percentage points. Six studies reported intervention and comparison group outcomes expressed as an odds ratio for tobacco use at follow-up. ^117, ^ ^118, ^ ^119, ^ ^120, ^ ^121, ^ ^127, ^ Two studies did not find any effect on tobacco use behaviors from exposure to the intervention. ^117, ^ ^118, ^ In four studies, the follow-up periods ranged from 2 to 4 years, and the adjusted odds ratios were similar in magnitude and direction (range 0.49 to 0.74: median 0.60). ^119, ^ ^120, ^ ^121, ^ ^127, ^ Finally, one study observed an absolute percentage difference of -11 percentage points in group mean tobacco use prevalence at 15-year follow-up for students who received a school education program and were exposed to community and mass media education interventions to reduce cardiovascular disease risk factors. ^128, ^

All seven of the studies evaluating mass media campaigns of two or more years' duration observed a reduction in tobacco use prevalence in the intervention group when compared to the control group. ^119, ^ ^120, ^ ^124, ^ ^125, ^ ^127, ^ ^128, ^ ^133, ^ The observed differences were more consistent and slightly greater in magnitude of effect for both tobacco use prevalence (range -2.4 to -11, median -8.0 percentage points) and in the odds ratios (range of outcomes 0.49 to 0.74, median result 0.74).

The contributions of individual components to the overall effectiveness of the interventions cannot be attributed.

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings and populations. Interventions were performed in the United States, ^115, ^ ^116, ^ ^117, ^ ^118, ^ ^119, ^ ^121, ^ ^122, ^ ^124, ^ ^125, ^ ^127, ^ Norway, ^120, ^ and Finland. ^128, ^ Interventions included statewide campaigns in Florida, ^116, ^ Massachusetts, ^127, ^ and Minnesota. ^124, ^ ^125, ^ Community and regional interventions were conducted in the Southeast, ^115, ^ Northeast, ^119, ^ Midwest, ^121, ^ and ^122, ^ in Montana ^119, ^ and Southern California. ^117, ^ ^118, ^ Interventions were initiated in the 1990s, ^116, ^ ^120, ^ ^127, ^ in the 1980s, ^115, ^ ^117, ^ ^118, ^ ^119, ^ ^121, ^ ^122, ^ ^124, ^ ^125, ^ and in the 1970s. ^128, ^ Outcomes were evaluated in representative samples of adolescents identified in the general population ^115, ^ ^127, ^ and in representative or selected samples of schools. ^116, ^ ^117, ^ ^118, ^ ^119, ^ ^120, ^ ^121, ^ ^122, ^ ^124, ^ ^125, ^ ^128^ Outcomes were evaluated in student populations recruited or surveyed before grade 6, ^119^ grade 6-7, ^116, ^ ^117, ^ ^118, ^ ^121, ^ ^122, ^ ^125, ^ ^128^ or after grade 7. ^116, ^ ^120, ^ ^124, ^ ^125^ Outcomes from the two most recent studies demonstrate a greater benefit among younger adolescents. ^116, ^ ^127^ Evaluation of the Florida campaign provides evidence of effectiveness of mass media campaigns among girls, boys, whites, blacks, and Hispanics. ^116, ^ ^133^

#### Review of evidence: other positive or negative effects

Mass media campaigns are effective in reducing population consumption of tobacco products and in increasing cessation in adult tobacco users (see Part III: Strategies to Increase Tobacco Use Cessation). Messages and broadcast times that are effective for children and adolescents, however, may have less or no effect on adult tobacco use. No other positive or negative effects were identified in this review.

#### Review of evidence: economic

One four-year study ^148^ conducted in Montana, New York, and Vermont compared the effect of a mass media campaign combined with a school smoking prevention program to a school smoking prevention program alone, on students from grades 5-7 through grades 8-10. Students were followed for two years after conclusion of the intervention. Costs included personnel, travel, data entry, message research and development, and television and radio advertising. The absolute percentage point change was -5.5 percentage points in smoking initiation (tobacco use prevalence was 25% in the comparison groups at follow-up). Adjusted program cost per smoker averted was $6,069, and the adjusted program cost per quality-adjusted life year (QALY) was $333. Based on the explicit quality assessment criteria used in developing the Community Guide, this study was classified as very good. ^90^ Study details, adjusted results, and quality scoring are listed online in the economic summary table provided at the website: www.thecommunityguide.org. (See also Appendix C, Interpreting the Economic Data.)

#### Barriers to intervention implementation

The main barrier to implementation of mass media campaigns is the cost of purchasing broadcast time. The costs of developing and test marketing messages can be offset by cooperation between tobacco prevention and control programs. Programs can lower message development costs, for example, by using existing television, radio, print, and outdoor ads from CDC's Media Campaign Resource Center, a clearinghouse of high-quality materials produced by states and other organizations. ^5^

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence exists that mass media campaigns are effective in reducing tobacco use prevalence in adolescents, when combined with other interventions. The contribution of individual components to the overall effectiveness of these interventions cannot be attributed.

### Research Issues for Strategies to Reduce Tobacco Use Initiation

#### Effectiveness

The effectiveness of increasing the unit price of tobacco products and mass media campaigns in reducing tobacco use by adolescents is established. Important questions remain regarding the composition and content of effective campaigns and the effectiveness in different settings and populations. Some issues raised by others ^4^ ^157^ overlap with questions generated as a result of this review.

- What interventions are most effective in combination with mass media campaigns? What interventions are least effective?
- What are the relative effects of these interventions on adolescent initiation, consumption, access to tobacco products, and cessation?
- What is the required intensity (frequency of spots and the broadcast exposure) of media messages for an effective campaign?
- What are the independent contributions of particular intervention features (e.g., components, content, intensity, and duration) to overall intervention effectiveness?
- What are the most effective ways to maintain reductions in youth tobacco use into young adulthood?
- Does tobacco use in adults respond to mass media campaigns that are youth-focused?

#### Applicability

The effectiveness of these interventions should be applicable in most settings and populations. However, there could be differences in the effectiveness of these interventions for specific subgroups of the population. Remaining questions regarding the applicability of these interventions in various settings and populations are:

- Are there differences in the responses of adolescents to tobacco product price increases by age, race, and ethnicity?
- Are the effects of mass media campaigns on adolescents by gender, race, and ethnicity similar to or different from those observed in Florida?

#### Other positive or negative effects

The studies in these reviews did not provide information on other positive or negative effects. Research questions pertinent to interventions to increase the price of tobacco products are presented in the section on Strategies to Increase Tobacco Use Cessation. Some issues generated by the review of mass media campaigns are:

- Do mass media campaigns that target children and adolescents result in increases in tobacco initiation among young adults, by delaying the age of initiation?
- What are the most effective ways to maintain reductions in youth tobacco use into young adulthood?

#### Economic evaluations

Available economic information was limited to a single study of mass media campaigns. Therefore, considerable research is warranted regarding the following questions:

- Are the costs and cost-effectiveness, net cost, or net benefit of mass media campaigns similar to or substantially different from those that have been previously reported?
- How do the costs per tobacco user averted compare with other tobacco prevention strategies?
- How do specific characteristics of mass media campaigns contribute to economic efficiency?
- What combinations of components in multicomponent interventions are most cost-effective?

#### Barriers

The strategies evaluated in this section require political action and support. Research issues generated in this review include:

- What characteristics are effective in successful legislative and referendum campaigns?
- How can adequate funding levels be maintained for mass media campaigns?

#### Methods of intervention research

Evaluations of mass media campaigns should provide information on the costs, scale, duration, and content of the campaign. Researchers should identify concurrent tobacco control efforts, especially excise taxes or changes in tobacco product price, and attempt to control for these changes in their analyses.

### Additional Interventions Under Evaluation

The Task Force is currently reviewing the evidence of effectiveness of three additional interventions that may affect tobacco product use among adolescents. Youth access restrictions include laws that regulate and enforce bans on the sale of tobacco products to, or their purchase or consumption by, children and adolescents. School-based education includes all efforts in school settings to educate and motivate young people to remain tobacco-free. Tobacco industry restrictions focus on laws that regulate tobacco product content, labeling, promotion, and advertising. The Task Force evaluations and conclusions on these strategies will be released later this year.

## Part III. Strategies to Increase Tobacco Use Cessation

Interventions to increase tobacco use cessation include strategies to increase the number of tobacco users who attempt to quit, strategies to improve the success rate of individual cessation attempts, and strategies to achieve both of these goals. Two interventions reviewed in this report are appropriate for communities: increasing the unit price for tobacco products, and mass media education. The Task Force also reviewed interventions appropriate for implementation in health care systems, which are included in this report: (1) provider reminder systems when implemented alone; (2) provider education programs when implemented alone; (3) provider reminder systems and provider education programs when implemented together, with or without patient education materials; (4) provider feedback systems; and (5) reducing patient out-of-pocket costs for effective cessation therapies. The Task Force also reviewed one intervention, patient telephone cessation support, which is appropriate for both communities and health care systems.

### Increasing the Unit Price of Tobacco Products

#### Definition

Interventions to increase the unit price of tobacco products include municipal, state, and federal legislation that raises the excise tax on these products. Although other factors also affect tobacco product pricing, excise tax increases historically have resulted in an equivalent or larger increase in tobacco product price. ^99^

#### Background

Excise taxes on tobacco products make the continued use of tobacco products less attractive to users. In the United States, excise tax increases have primarily occurred in individual states, as most legislative attempts at the federal level have been unsuccessful. State excise tax increases have occurred as a result of legislative action, and in some states as a result of statewide referendums. Referenda passed in California, Massachusetts, Oregon, and Arizona provided various proportions of excise tax funds by mandate or recommendation to support statewide education programs and mass media campaigns. ^100^

#### Review of evidence: effectiveness

Our search identified 56 papers regarding the effectiveness of increasing the price of tobacco products on tobacco use behaviors among individual smokers and general populations. ^101, ^ ^107, ^ ^108, ^ ^111, ^ ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164, ^ ^165, ^ ^166, ^ ^167, ^ ^168, ^ ^169, ^ ^170, ^ ^171, ^ ^172, ^ ^173, ^ ^174, ^ ^175, ^ ^176, ^ ^177, ^ ^178, ^ ^179, ^ ^180, ^ ^181, ^ ^182, ^ ^183, ^ ^184, ^ ^185, ^ ^186, ^ ^187, ^ ^188, ^ ^189, ^ ^190, ^ ^191, ^ ^192, ^ ^193, ^ ^194, ^ ^195, ^ ^196, ^ ^197, ^ ^198, ^ ^199, ^ ^200, ^ ^201, ^ ^202, ^ ^203, ^ ^204, ^ ^205, ^ ^206, ^ ^207, ^ ^208, ^ ^209^ A number of papers, however, conducted analyses on the same datasets for similar, identical, or overlapping periods of time. For the purposes of this evaluation, the Task Force consolidated papers into aggregate studies based on similarities in location, the period of study, and the dataset employed (details available at www.thecommunityguide.org). For example, we considered all of the identified papers evaluating activities in California in the period 1989-1994 a single aggregate study. ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164^ After consolidating overlapping papers, the body of evidence consisted of 22 aggregate studies. Five studies were excluded because of limitations in execution quality. ^204, ^ ^205, ^ ^206, ^ ^207, ^ ^208^ Details of the 17 qualifying studies, including the selection of representative outcome measurements, are available at www.thecommunityguide.org.

The 17 qualifying studies include consolidated evaluations of the effect of tobacco product price on tobacco use in the states of California, ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164^ Massachusetts, ^165^ Oregon, ^166^ 11 Western states, ^167^ national evaluations conducted in the 1990s, ^101, ^ ^168, ^ ^169^ national evaluations conducted in the 1980s, ^107, ^ ^108, ^ ^111, ^ ^170, ^ ^171, ^ ^172, ^ ^173, ^ ^174, ^ ^175, ^ ^176, ^ ^177, ^ ^178, ^ ^179, ^ ^180, ^ ^181, ^ ^182, ^ ^183, ^ ^184^ national evaluations conducted in the 1970s, ^185, ^ ^186, ^ ^187, ^ ^188, ^ ^189, ^ ^190, ^ ^191, ^ ^192, ^ ^193^ three studies conducted in Canada, ^194, ^ ^195, ^ ^196^ three studies conducted in the United Kingdom, ^197, ^ ^198, ^ ^199^ and single studies conducted in Austria, ^200^ Finland, ^201^ Switzerland, ^202, ^ ^203^ and New Zealand. ^209^

The most common measurement described in the body of evidence to estimate the effect of tobacco product price increases was the price elasticity of demand (the percentage change in consumption that results from a 1% change in price). In econometric analysis of tobacco product price increases (resulting from an excise tax increase, a tobacco industry price increase, or both), a negative price elasticity of demand estimate indicates a decrease in consumption. In studies that measure changes in tobacco product consumption (typically estimated from national or regional tobacco sales figures), observed changes capture the combined effect of increases in cessation, decreases in initiation, and reduced consumption by continuing users. In studies that use data from individuals to measure tobacco use prevalence and quantity consumed, the price elasticity of demand calculations include distinct estimates for participation (i.e., tobacco use prevalence) and tobacco product consumption (e.g., cigarettes smoked per day), and overall estimates (participation and consumption).

Thirteen of the seventeen consolidated studies included measurements of price elasticity of demand. ^101, ^ ^107, ^ ^108, ^ ^111, ^ ^111, ^ ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164, ^ ^167, ^ ^168, ^ ^169, ^ ^170, ^ ^171, ^ ^172, ^ ^173, ^ ^174, ^ ^175, ^ ^176, ^ ^177, ^ ^178, ^ ^179, ^ ^180, ^ ^181, ^ ^182, ^ ^183, ^ ^184, ^ ^185, ^ ^186, ^ ^187, ^ ^188, ^ ^189, ^ ^190, ^ ^191, ^ ^192, ^ ^193, ^ ^194, ^ ^197, ^ ^198, ^ ^199, ^ ^200, ^ ^201, ^ ^202, ^ ^203, ^ ^209^ Ten aggregate studies provided measurements based on cigarette sales data, with a range of price elasticity estimates of -0.27 to -0.76 and a median estimate of -0.41 (suggesting that a 10% increase in product price would result in a 4.1% decrease in population consumption). ^101, ^ ^107, ^ ^108, ^ ^111, ^ ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164, ^ ^167, ^ ^168, ^ ^169, ^ ^170, ^ ^171, ^ ^172, ^ ^173, ^ ^174, ^ ^175, ^ ^176, ^ ^177, ^ ^178, ^ ^179, ^ ^180, ^ ^181, ^ ^182, ^ ^183, ^ ^184, ^ ^185, ^ ^186, ^ ^187, ^ ^188, ^ ^189, ^ ^190, ^ ^191, ^ ^192, ^ ^193, ^ ^194, ^ ^200, ^ ^201, ^ ^202, ^ ^203, ^ ^209^ Seven studies ^101, ^ ^107, ^ ^108, ^ ^111, ^ ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164, ^ ^168, ^ ^169, ^ ^170, ^ ^171, ^ ^172, ^ ^173, ^ ^174, ^ ^175, ^ ^176, ^ ^177, ^ ^178, ^ ^179, ^ ^180, ^ ^181, ^ ^182, ^ ^183, ^ ^184, ^ ^185, ^ ^186, ^ ^187, ^ ^188, ^ ^189, ^ ^190, ^ ^191, ^ ^192, ^ ^193, ^ ^197, ^ ^198, ^ ^199^ provided measurements based on individual responses, although one study provided only an overall price elasticity of demand estimate. ^199^ For the overall price elasticity estimate the values ranged from +0.5 to -0.84 with a median of -0.42. For the price elasticity of participation, the range was -0.08 to -0.26 with a median of -0.15. For the estimate of quantity consumed, the values ranged from -0.09 to -0.61 with a median of -0.19.

Overall, this body of evidence documented consistent effects of increases in tobacco product price on reducing tobacco use, regardless of the measurements reported or calculated, the setting or period of time evaluated, or differences in the control of potential confounders. Three aggregate studies, which used information collected in the 1990s, provide more recent price elasticity of demand estimates of the effect of tobacco product price increases on reducing tobacco use. ^101, ^ ^158, ^ ^159, ^ ^160, ^ ^161, ^ ^162, ^ ^163, ^ ^164, ^ ^168, ^ ^169, ^ ^194^ Price elasticity estimates from tobacco sales figures provided in these studies range from -0.30 (state tax elasticity in California) to -0.42 (US national estimate) with a median of -0.40. Results from two papers within the US national set ^101^ ^169^ based on individual responses in two national surveys were very similar, with estimates of -0.29 and -0.25 overall, -0.14 and -0.15 for participation, and -0.15 and -0.10 for quantity consumed.

Four studies provided measurements other than price elasticity of demand in assessing the impact of tobacco product price changes on tobacco use. ^165, ^ ^166, ^ ^195, ^ ^196^ One study reported the effect of federal and provincial excise tax increases on tax paid sales of cigarettes in Alberta, Canada. ^196^ In the period 1985-1995, the price index for cigarettes increased from 1.00 (1985-1986 baseline) to 1.78 while the consumption index decreased from 1.00 to 0.58. A second study from Canada in 1994-1995, following a federal excise tax reduction, compared tobacco use in survey samples in provinces that reduced excise taxes on cigarettes with provinces that did not. ^195^ Although tobacco use declined in all of the provinces over the study period, the rate of decline slowed significantly in provinces that reduced the excise tax on cigarettes. Finally, the states of Massachusetts and Oregon reported reductions in population consumption of tobacco following increases in the excise tax for tobacco products and implementation of multicomponent tobacco control programs that included a mass media campaign. ^165^ ^166^ Compared to the rest of the United States, the relative percent decreases in tobacco consumption were -12.8% and -9.8% over periods of 4 years and 2 years, respectively. The independent effect of the excise tax change on tobacco consumption could not be determined in these studies.

#### Review of evidence: applicability

The individual papers included in the qualifying studies were used to provide information on the applicability of this intervention to different products, settings, and populations. All of the qualifying studies evaluated the effect of price on the consumption of cigarettes. In addition, studies evaluated the effect of price increases on consumption of smokeless tobacco, ^107, ^ ^111^ cigars, ^201^ and pipe tobacco. ^201^ Studies demonstrated the effectiveness of state excise tax increases ^159, ^ ^161, ^ ^162, ^ ^165, ^ ^168, ^ ^177^ and federal excise tax increases. ^160^ ^168^ Most studies using individual data employed representative samples of state or national populations. Studies have demonstrated effectiveness in stratified analyses for whites, ^101^ blacks, ^101, ^ ^162^ Hispanics, ^101, ^ ^162^ men, ^101, ^ ^162, ^ ^187, ^ ^191, ^ ^198^ and women. ^101, ^ ^187, ^ ^191, ^ ^198, ^ ^199^ Studies also demonstrated effectiveness in persons with incomes below median, ^101, ^ ^169^ less than a high school education, ^188^ and across most social classes. ^198, ^ ^199^

#### Review of evidence: other positive or negative effects

Increasing the unit price for tobacco products will decrease tobacco use in adolescents and young adults (see "Part II: Strategies to Reduce Tobacco Use Initiation"). Increases in illegal cross-border transport and sale of untaxed tobacco products (smuggling) are potential negative effects of increases in tobacco product excise taxes. No recent studies of the effects of organized smuggling in the United States were identified in this review, and an analysis in 1985 reported a significant reduction in activity following federal legislation in 1978. ^210^

This review identified several additional effects of tobacco product price increases that might reduce (but would not eliminate) the potential health benefits caused by increases in cessation and reductions in consumption. These effects include: (1) legal, individual cross-border purchases of tobacco products; (2) substitution of tobacco products (e.g., smokeless tobacco for cigarettes) created by unequal taxation on different kinds of tobacco products; ^111^ and (3) modification of individual tobacco use behaviors, such as smoking cigarettes longer or changing to a higher-tar, higher-nicotine brand. ^174^

#### Review of evidence: economic

Econometric analyses were used to evaluate the effectiveness of this economic intervention. The results are reported above in the section, "Review of evidence: effectiveness."

#### Barriers to intervention implementation

Excise tax increases require passage of legislation or statewide referendum. Efforts to increase the federal excise tax have largely been unsuccessful. Political opposition is well organized and funded at both the federal and state levels. Reports of state tobacco tax initiatives, successful and unsuccessful, have been published. ^17, ^ ^100, ^ ^112, ^ ^113^

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence demonstrates that increasing the unit price for tobacco products is effective in increasing tobacco use cessation and in reducing consumption.

### Mass Media Education

Mass media education consists of dissemination, through broadcast and print media, of cessation information to motivate tobacco product users to quit. This evidence review distinguished among three subtypes of mass media interventions (campaigns, cessation series, and cessation contests) that differ in the duration, intent, and intensity of the media messages. Each is addressed separately below.

### Mass Media Education: Campaigns

#### Definition

Campaigns are mass media interventions of an extended duration, using brief, recurring messages to inform and to motivate tobacco product users to quit. Message content is developed through formative research, and message dissemination includes the use of either paid air time and print space (advertisements), donated time and space (public service announcements), or a combination of the two. Campaigns can be combined with other interventions, such as an excise tax increase, or additional community education efforts.

#### Background

The historical foundation for mass media education to reduce tobacco use is the national experience from 1966 through 1970 of a long-duration, high-intensity anti-smoking broadcast campaign that resulted from a complaint to the Federal Communications Commission (FCC). The complaint requested application of the Fairness Doctrine to mandate reply time to counter cigarette advertising on television and radio. In June 1967, the FCC initiated a mandate (upheld on appeal) that required broadcasters to provide broadcast time free of charge for anti-smoking messages. At the peak, anti-smoking messages were broadcast (often in prime time) at a rate of one message for every three cigarette commercials. This policy lasted until 1971, when a ban on cigarette broadcast advertising went into effect. Cigarette consumption declined each year during the campaign and rose again after the cigarette advertising ban ended free access to broadcast time for anti-smoking messages. ^211^ ^212^ ^213^

#### Review of evidence: effectiveness

Our search identified 24 studies regarding the effectiveness of mass media campaigns in reducing tobacco use. ^164, ^ ^165, ^ ^166, ^ ^214, ^ ^215, ^ ^216, ^ ^217, ^ ^218, ^ ^219, ^ ^220, ^ ^221, ^ ^222, ^ ^223, ^ ^224, ^ ^225, ^ ^226, ^ ^227, ^ ^228, ^ ^229, ^ ^230, ^ ^231, ^ ^232, ^ ^233, ^ ^234^ An additional 14 papers provided more information on an already-included study. ^152, ^ ^161, ^ ^235, ^ ^236, ^ ^237, ^ ^238, ^ ^239, ^ ^240, ^ ^241, ^ ^242, ^ ^243, ^ ^244, ^ ^245, ^ ^246^ Four papers with limited quality of execution, ^214, ^ ^219, ^ ^227, ^ ^233^ and two papers with least suitable study designs ^216, ^ ^232^ were not included in the body of evidence. Three studies measured the effect of a mass media campaign in increasing use of a telephone cessation information service, ^215, ^ ^229, ^ ^231^ and these results are described later in this section, in the review of multicomponent interventions including patient telephone support. Details of the remaining 15 qualifying studies are provided at the website: www.thecommunityguide.org.

All of the qualifying studies evaluated the effectiveness of a mass media campaign either coordinated with or concurrent with other interventions. These other interventions included an excise tax increase (6 studies), ^164, ^ ^165, ^ ^166, ^ ^220, ^ ^223, ^ ^225^ community education programs such as the distribution of self-help cessation information (12 studies), ^164, ^ ^165, ^ ^166, ^ ^217, ^ ^218, ^ ^220, ^ ^223, ^ ^224, ^ ^225, ^ ^228, ^ ^230, ^ ^234^ individual or group cardiovascular disease risk factor reduction or smoking cessation counseling (7 studies), ^218, ^ ^221, ^ ^222, ^ ^223, ^ ^224, ^ ^226, ^ ^228^ and other mass media efforts (2 studies). ^218, ^ ^234^

The 15 qualifying studies provided 15 measurements of changes in tobacco use, consisting of 5 measurements of changes in individual tobacco use cessation, 3 measurements of changes in population consumption (measured by statewide sales of cigarettes), and 7 measurements of changes in the prevalence of tobacco use in the study population. Two studies ^164^ ^165^ provided both measurements of population consumption and tobacco use prevalence. For these studies, the measurements of population consumption are reported.

Five studies evaluated the effectiveness of mass media campaigns combined with additional interventions in increasing tobacco use cessation in groups of recruited tobacco users. ^217, ^ ^221, ^ ^224, ^ ^226, ^ ^228^ The duration of the interventions ranged from less than 1 year to 5 years. Cessation rates in the intervention group ranged from 3.9% (confirmed) to 50% (self-reported), with a median of 7% in follow-up periods of 6 months to 5 years (median, 14 months). The absolute percentage differences in cessation between intervention group participants and comparison group participants (who were potentially exposed to the media component in 3 studies) ranged from -2 percentage points to +35 percentage points, with a median difference of +2.2 percentage points.

Three studies evaluated the effectiveness of mass media campaigns in reducing tobacco consumption (as measured by state-wide sales of cigarettes) in a state population. ^164, ^ ^165, ^ ^166^ These studies evaluated the effect of ongoing state-funded mass media campaigns coordinated with excise tax increases and funding for community and school-based education programs. All three studies, with follow-up periods of 2-8 years, observed decreases in state per capita consumption of cigarettes compared to per capita consumption in the rest of the United States. The observed differences ranged from -9 cigarette packs per capita per year (-9.8% relative decrease) to -20.4 packs per capita per year (-17.5% relative decrease), with a median of -15 packs per capita per year (-12.8% relative decrease).

Seven studies evaluated the effectiveness of mass media campaigns in reducing the prevalence of tobacco use in study populations. ^218, ^ ^220, ^ ^222, ^ ^223, ^ ^225, ^ ^230, ^ ^234^ These include investigations conducted in California (including targeted campaigns for Vietnamese and Hispanic populations as part of the larger California media campaign previously described), ^218, ^ ^220, ^ ^223, ^ ^225^ Minnesota, ^222^ Australia, ^230^ and Finland. ^234^ Five studies reported differences in tobacco use prevalence compared with a concurrent population, ^218, ^ ^220, ^ ^222, ^ ^225, ^ ^234^ and two studies reported before-after changes in a single study population. ^223, ^ ^230^

Six of the seven studies observed decreases in tobacco use prevalence, ^220, ^ ^222, ^ ^223, ^ ^225, ^ ^230, ^ ^234^ over study periods that ranged from 6 months to 20 years (median 6 years). In the five studies with concurrent comparison populations, absolute percentage differences in tobacco use prevalence reported ranged from +0.2 to -7 percentage points (median -3.4 percentage points). ^218, ^ ^220, ^ ^222, ^ ^225, ^ ^234^ In the two studies without a concurrent comparison population, the absolute percentage changes observed over time were -2.5 ^230^ and -4.7 percentage points. ^223^

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings and populations. All of the qualifying studies focused on differences or changes in the consumption and use of cigarettes. Studies included campaigns conducted nationwide in Scotland, ^221^ statewide in the United States, ^164, ^ ^165, ^ ^166^ region-wide in the United States ^217^ and Finland, ^234^ in large cities, ^230^ and in smaller communities and localized populations. ^218, ^ ^220, ^ ^222, ^ ^223, ^ ^224, ^ ^225, ^ ^226, ^ ^228^

Evidence of effectiveness from the state campaigns should be generally applicable to the U.S. population. Studies have been performed among specific U.S. populations including Hispanics ^223, ^ ^224^ and Vietnamese men. ^220, ^ ^225^

#### Review of evidence: other positive or negative effects

Several studies ^215, ^ ^217, ^ ^229, ^ ^231^ observed significant increases in use of telephone cessation information or support services when the mass media messages directed viewers to call for further information or support. The mass media campaigns in California, Oregon, and Massachusetts included messages targeting children and adolescents, and messages about the health effects of exposure to environmental tobacco smoke.

#### Review of evidence: economic

Two studies were included for review, one conducted in the Netherlands ^247^ and the other in Scotland. ^248^ Both studies evaluated community-wide interventions to increase cessation among adult tobacco users. Both studies reported program costs per quitter. In addition, one study ^248^ reported program cost per life-years saved, which was converted to dollars per QALY based on preference weights provided by Fiscella and Franks. ^249^

The intervention conducted in the Netherlands ^247^ evaluated the effect of a mass media campaign, self-help manual, hotline, and a 9-session group cessation program. Self-reported 7-day abstinence was determined at 6-month follow-up. Costs included were wages, overhead, calls to the hotline, participant time, transportation, and charges for the group session. The effect size was estimated as the difference in smoking prevalence before and after the intervention. The self-reported cessation rate was 11% for participants using the self-help manual alone and 22% for participants using the self-help manual combined with the cessation program. Based on this effect size, adjusted program cost per quitter ranged from $796 to $1593. Based on the explicit quality assessment criteria used in developing the Community Guide, this study was classified as satisfactory. ^90^

The study conducted in Scotland ^248^ consisted of a mass media campaign, telephone helpline, and information booklet. At the 12-month follow-up, 9.8% of program participants reported having quit smoking for at least 6 months. Costs included research, production, design fees, printing, dissemination, staff salaries, and overhead. The adjusted program costs per quitter in this study ranged from $298 to $655. Adjusted program costs per QALY ranged from $151 to $328. The range was based on lower and upper bound estimates of adult participants. Based on the explicit quality assessment criteria used in developing the Community Guide, this study was classified as satisfactory. ^90^ Study details, adjusted results, and quality scoring are provided at the website: www.thecommunityguide.org. (See also Appendix C, Interpreting the Economic Data.)

#### Barriers to intervention implementation

The primary barriers to the implementation of mass media campaigns are obtaining and preserving the funding needed to develop and to maintain an extended duration, high-intensity campaign using paid and targeted broadcast times for messages that resonate with target audiences. The barriers encountered by the tobacco control program in the state of California provide important lessons on the need for both public and political support and vigilance in maintaining an effective campaign. ^250^ ^251^

Cooperation between tobacco control programs can reduce program development costs. Programs can lower message development costs, for example, by using existing television, radio, print, and outdoor ads from CDC's Media Campaign Resource Center, a clearinghouse of high-quality materials produced by states and other organizations. ^5^

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence exists that mass media campaigns combined with other interventions are effective in increasing tobacco use cessation and in reducing consumption of tobacco products.

### Mass Media Education: Cessation Series

#### Definition

Cessation series are mass media interventions using recurring instructional segments to recruit, inform, and motivate tobacco product users to initiate and maintain cessation efforts. Cessation series can be coordinated with pre-series broadcast or print promotion, community education such as distribution of self-help cessation materials, and organization of cessation groups in the community. The series can extend for a period of several weeks to several months, and techniques include nightly or weekly segments on news or informational broadcasts providing expert advice or peer group experiences on a variety of cessation issues (e.g., dealing with the symptoms of withdrawal).

#### Background

The goals of smoking cessation series are to increase the number of tobacco users who attempt to quit and to increase the number of quitters who succeed. The series can provide motivation to tobacco product users to join in a community-wide targeted quit effort. Over the course of the broadcasts, viewers can receive ongoing support and assistance from cessation experts and recruited peers.

#### Review of evidence: effectiveness

Our search identified 20 studies regarding the effectiveness of cessation series in increasing tobacco use cessation. ^244, ^ ^252, ^ ^253, ^ ^254, ^ ^255, ^ ^256, ^ ^257, ^ ^258, ^ ^259, ^ ^260, ^ ^261, ^ ^262, ^ ^263, ^ ^264, ^ ^265, ^ ^266, ^ ^267, ^ ^268, ^ ^269, ^ ^270^ Ten additional papers provide information on an already-included study. ^271, ^ ^272, ^ ^273, ^ ^274, ^ ^275, ^ ^276, ^ ^277, ^ ^278, ^ ^279, ^ ^280^ Ten studies with limited execution, ^244, ^ ^252, ^ ^254, ^ ^257, ^ ^258, ^ ^261, ^ ^263, ^ ^265, ^ ^266, ^ ^268^ and one study with a least-suitable study design, ^255^ were not included in the body of evidence. Details of the nine qualifying studies ^253, ^ ^256, ^ ^259, ^ ^260, ^ ^262, ^ ^264, ^ ^267, ^ ^269, ^ ^270^ are provided at the website: www.thecommunityguide.org.

All of the qualifying studies evaluated the effectiveness of cessation series combined with other interventions, such as community education (typically access to or distribution of self-help cessation manuals), ^253, ^ ^256, ^ ^259, ^ ^260, ^ ^262, ^ ^267, ^ ^269, ^ ^270^ organized cessation groups or programs, ^256, ^ ^260, ^ ^262, ^ ^264, ^ ^267, ^ ^269, ^ ^270^ or telephone cessation support. ^256, ^ ^260^ Eight studies evaluated televised cessation series broadcast over periods extending from 20 days to 3 months, ^256, ^ ^259, ^ ^260, ^ ^262, ^ ^264, ^ ^267, ^ ^269, ^ ^270^ and one study evaluated a week-long newspaper cessation series. ^253^

Five of the nine qualifying studies present evaluations of broadcast cessation series conducted in the Chicago metropolitan area (in one of three waves) between 1985 and 1987. ^256, ^ ^262, ^ ^267, ^ ^269, ^ ^270^ These studies were evaluated separately because of differences in the study populations or settings.

Of the nine qualifying studies, only one investigation compared exposed and unexposed groups of recruited participants. ^259^ That study observed no significant difference in self-reported cessation rates at 6-month follow-up. One study compared self-reported cessation based on recalled exposure to various campaign interventions. ^260^ Persons who recalled watching the cessation series were more likely to report sustained cessation at interview (odds ratio 1.36; 95% CI 1.13, 1.65). In five studies, smokers in both the intervention and comparison groups were exposed to the cessation series, with participants in the intervention group receiving additional interventions, such as small group sessions. ^256, ^ ^262, ^ ^264, ^ ^267, ^ ^270^ These studies reported absolute percent differences in cessation that ranged from +4 to +8 percentage points (median, +5 percentage points) with follow-up periods of 4 to 24 months (median, 12 months). However, these studies share a potential limitation in comparing smokers motivated to quit (enrolled or offered cessation group support) with smokers potentially less motivated to quit. Of the two remaining studies, one reported differences in cessation by intervention setting, with all of the participants receiving a similar intervention. ^269^ The other study reported an increase in cessation attempts in persons who recalled exposure to a week-long newspaper cessation series. ^253^

The qualifying studies provided insufficient evidence of effectiveness of the broadcast series in increasing tobacco use cessation. The differences in cessation observed in these studies might be the result of (1) baseline differences in motivation to quit between intervention and comparison smokers, and (2) the small group cessation sessions provided to the intervention group participants.

#### Review of evidence: other positive or negative effects

No additional information regarding other positive or negative effects was identified in this review.

#### Conclusion

According to the Community Guide's rules of evidence, the available studies provide insufficient evidence to assess the effectiveness of cessation series in reducing tobacco use. Evidence is insufficient because of (1) inconsistent results, and (2) inadequate comparison populations/groups.

### Mass Media Education: Cessation Contests

#### Definition

Cessation contests are short-duration, community-wide events using mass media for the promotion, recruitment, and motivation of tobacco product users to participate in a targeted cessation date or period. This evaluation included contests that offered additional incentives for participation and successful cessation, as well as targeted quit events conducted without additional incentives.

#### Background

Cessation contests are included in this section because this intervention uses mass media (as well as small media such as posters and flyers) as the primary tool for promotion and recruitment of tobacco product users in the community. Contests can work to increase cessation in the community by changing attitudes of tobacco product users about cessation, recruiting tobacco product users to initiate a quit attempt, and motivating those who attempt to quit to remain abstinent (through incentives or by mobilizing support from family, friends, and other participants).

#### Review of evidence: effectiveness

Our search identified 17 studies regarding the effectiveness of tobacco cessation contests. ^257, ^ ^281, ^ ^282, ^ ^283, ^ ^284, ^ ^285, ^ ^286, ^ ^287, ^ ^288, ^ ^289, ^ ^290, ^ ^291, ^ ^292, ^ ^293, ^ ^294, ^ ^295, ^ ^296^ Three additional papers provided information on an already-included study. ^297, ^ ^298, ^ ^299^ Eleven studies measuring tobacco use cessation in contest participants in the absence of a comparison group were excluded from further evaluation. ^281, ^ ^282, ^ ^283, ^ ^284, ^ ^286, ^ ^287, ^ ^288, ^ ^290, ^ ^293, ^ ^294, ^ ^296^ Five studies with limitations in quality of execution were not included in the evaluation of effectiveness. ^257, ^ ^285, ^ ^289, ^ ^291, ^ ^292^ Details of the one qualifying study ^295^ are provided at the website: www.thecommunityguide.org.

The single qualifying study evaluated a multicomponent smoking cessation program in New York City. Interventions included a cessation manual and video, telephone cessation support, and the opportunity to participate in smoking cessation contests. The contest participation rate was 13% and entering the contest was significantly associated with self-reported cessation at 6-month followup (odds ratio 3.0; 95% CI 1.7, 5.4). Overall, the absolute percentage difference in self-reported cessation at 6-month follow-up was +3.3 percentage points compared with smokers who received only general health education materials.

#### Review of evidence: other positive or negative effects

No information on other positive or negative effects was identified in this review.

#### Conclusion

According to the Community Guide's rules of evidence, the available studies provide insufficient evidence to assess the effectiveness of cessation contests in increasing tobacco use cessation. Evidence is insufficient because of the small number of qualifying studies.

### Strategies Appropriate for Health Care Systems and Providers

The Task Force reviewed a variety of interventions that can be implemented by health care systems and providers to increase or improve cessation of tobacco use by patients. This report does not include an evaluation of the effectiveness of provider counseling to tobacco-using patients or the effectiveness of specific clinical therapies, which have been thoroughly reviewed by others. ^4, ^ ^14, ^ ^15, ^ ^300^

### Health Care Systems/Providers: Provider Reminder Systems

#### Definition

Provider reminder systems include efforts to identify patients who use tobacco products and efforts to prompt providers to discuss and/or advise patients about cessation. Techniques by which reminders are delivered include chart stickers, vital sign stamps, medical record flow sheets, and checklists. The content of provider reminders can vary, and provider reminder systems are often combined with other interventions, such as provider education and patient education. Multicomponent interventions including provider reminders are considered below, in the section on Provider Reminder + Provider Education with or without Patient Education.

#### Background

Reminder systems prompt providers to interact with patients about tobacco use at every encounter. Reminders aim to increase recognition of patient tobacco use status, resulting in an increase in provider delivery of advice to quit. Because even brief provider advice to quit has a demonstrated effect on patient tobacco use cessation, ^14^ ^300^ increasing the delivery of advice by providers will increase the number of patients who quit.

#### Review of evidence: effectiveness

Our search identified eight studies evaluating the effectiveness of provider reminder systems when used alone. ^301, ^ ^302, ^ ^303, ^ ^304, ^ ^305, ^ ^306, ^ ^307, ^ ^308^ One paper with a least-suitable study design was not included in the body of evidence. ^303^ Details of the seven qualifying studies are provided at the website: www.thecommunityguide.org. The evaluated techniques for prompting providers were chart prompts or stickers, ^301, ^ ^306, ^ ^307, ^ ^308^ "expanded vital signs" that include tobacco use status, ^305^ and flowsheets. ^304, ^ ^307^ In one qualifying study, the intervention sites received an office consultation that encouraged implementation of a provider reminder system. Analysis was based on receipt of the consultation, not on actual implementation of the reminder system. ^302^

The 7 qualifying studies reported 4 measurements of differences in documentation of patient smoking status, ^301, ^ ^304, ^ ^306, ^ ^308^ 5 measurements of chart-documented or patient-reported provider delivery of advice to quit to tobacco-using patients, ^301, ^ ^302, ^ ^305, ^ ^307, ^ ^308^ and 1 measurement of patient smoking cessation. ^307^ For determination of patient smoking status, 4 studies ^301, ^ ^304, ^ ^306, ^ ^308^ measured absolute percentage differences of +26 to +57.6 percentage points (median, +32.5 percentage points) in periods extending from 8 to 24 months post implementation (median, 15 months). For provider delivery of advice to quit (Figure 3), 5 studies ^301, ^ ^302, ^ ^305, ^ ^307, ^ ^308^ observed differences that ranged from +7 to +31 percentage points (median, +13 percentage points) in assessments extending 2 to 24 months post implementation (median, 8 months). One study reported an absolute percentage difference in biochemically confirmed smoking cessation of +4 percentage points, 6 months post clinic visit. ^307^

Figure 3. Percentage point change in patient receipt of advice to quit tobacco use from providers attributable to provider reminders from studies that qualified for inclusion in this review

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different tobacco products, settings, and populations. Studies were conducted in the United States ^301, ^ ^302, ^ ^304, ^ ^305, ^ ^307, ^ ^308^ and Canada. ^306^ Studies were conducted in primary care clinics, ^302, ^ ^307^ family practice clinics, ^304, ^ ^305, ^ ^306, ^ ^308^ and in pulmonary clinics. ^301^ Most studies did not provide demographic information on the patient populations.

#### Review of evidence: other positive or negative effects

Two studies, in which provider reminders included other preventive services, observed increases in some or all of the prompted activities. ^304^ ^306^ Other positive or negative effects were not identified in this review.

#### Review of evidence: economic

We did not identify any economic evaluations reporting on cost, cost-effectiveness, cost-benefit, or cost utility in this review.

#### Barriers to intervention implementation

One potential barrier to the implementation of a provider reminder system is the administrative burden. Administrative burden was not identified as a problem in any of the qualifying studies, and most of the reminder systems (e.g., "expanded vital signs") were easily implemented.

#### Conclusion

According to the Community Guide's rules of evidence, sufficient scientific evidence documents that provider reminder systems when implemented alone are effective in increasing provider delivery of advice to quit to tobacco-using patients.

### Health Care Systems/Providers: Provider Education Only

#### Definition

Provider education involves giving information about tobacco and tobacco use cessation to providers, to increase their knowledge and change their attitudes and practices. Techniques by which information is delivered include lectures, written materials, videos, and continuing medical education seminars. Provider populations include physicians, nurses, physician assistants, health care students, and other office staff.

Provider education efforts are frequently combined with other interventions, such as provider reminders and patient education efforts. Multicomponent interventions including provider reminders are considered below, in the section on Provider Reminder + Provider Education with or without Patient Education.

#### Background

Provider education attempts to increase or improve providers' interactions with tobacco-using patients. Changes in provider performance could include increases in the identification of tobacco-using patients, increases in the delivery of advice to quit, improvement in the quality of providers' advice to quit, and both an increase and an improvement in providers' efforts to assist tobacco users' attempts to quit and to maintain abstinence.

#### Review of evidence: effectiveness

Our search identified 25 studies regarding the effectiveness of provider education interventions when implemented alone. ^302, ^ ^307, ^ ^309, ^ ^310, ^ ^311, ^ ^312, ^ ^313, ^ ^314, ^ ^315, ^ ^316, ^ ^317, ^ ^318, ^ ^319, ^ ^320, ^ ^321, ^ ^322, ^ ^323, ^ ^324, ^ ^325, ^ ^326, ^ ^327, ^ ^328, ^ ^329, ^ ^330, ^ ^331^ Two additional papers provided information on an already-included study. ^332, ^ ^333^ Five studies with limited quality of execution, ^310, ^ ^312, ^ ^315, ^ ^319, ^ ^328^ and four studies with least suitable study designs ^317, ^ ^321, ^ ^323, ^ ^331^ were not included in the body of evidence. Details on the 16 qualifying studies are provided at the website: www.thecommunityguide.org.

Provider education techniques evaluated in the qualifying studies include day-long seminars, ^302, ^ ^311^ lectures for practitioners, ^311, ^ ^314, ^ ^327^ lectures for resident physicians, ^307, ^ ^316, ^ ^318, ^ ^320, ^ ^326^ lectures and office visits or contacts, ^322, ^ ^329^ small group tutorial sessions, ^309, ^ ^324^ mock interviews with feedback, ^325, ^ ^330^ and education materials. ^313^ The total duration of the provider education sessions ranged from 2 hours to 3 days (median, 2.5 hours) in the 11 studies that provided this information.

The 16 qualifying studies reported a total of 19 measurements of changes in provider counseling skills or behaviors, and two measurements of patient tobacco use behaviors. Four studies measured changes or differences in cessation counseling skills or use of patient education materials, ^309, ^ ^313, ^ ^324, ^ ^325^ which were not considered in the evidence of effectiveness. Five studies measured differences in provider determination of patient smoking status, ^311, ^ ^318, ^ ^322, ^ ^326, ^ ^330^ with absolute percentage differences ranged from +0.1 to +35 percentage points (median, +8 percentage points). Ten studies reported differences in provider delivery of advice to quit (see Figure 4), ^302, ^ ^307, ^ ^311, ^ ^314, ^ ^316, ^ ^318, ^ ^320, ^ ^322, ^ ^329, ^ ^330^ with absolute percentage differences that ranged from -5 to +73 percentage points (median, +2.2 percentage points). Four of these 10 studies observed either no effect or a negative effect on provider delivery of advice to quit. ^302, ^ ^316, ^ ^329, ^ ^330^ Two studies reported differences in patient tobacco use cessation. ^307^ ^316^ Absolute percentage differences in cessation were +5.2 and +1.7 percentage points in follow-up periods of 3.5 months and 6 months, respectively.

Figure 4. Percentage point change in patient receipt of advice to quit tobacco use from providers attributable to provider education from studies that qualified for inclusion in this review

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings, provider populations, and patient populations. Settings have included HMOs, ^314^ academic centers, ^307, ^ ^316, ^ ^318, ^ ^320^ and private practices. ^302, ^ ^311, ^ ^329^ Studies have included such providers as medical and nursing students, ^309, ^ ^325, ^ ^327^ resident physicians, ^307, ^ ^316, ^ ^318, ^ ^320, ^ ^324, ^ ^326, ^ ^330^ physician practicioners, ^302, ^ ^311, ^ ^313, ^ ^314, ^ ^326, ^ ^329^ and non-physician practioners. ^329^ Physician specialties included internal medicine, ^307, ^ ^311, ^ ^324^ family practice, ^307, ^ ^311, ^ ^316, ^ ^320, ^ ^324^ and pediatrics. ^307, ^ ^318^ Four studies evaluated interventions targeting providers community-wide. ^311, ^ ^313, ^ ^322, ^ ^329^ Few studies provided information on the patient populations.

#### Review of evidence: other positive or negative effects

No information regarding other positive or negative effects was identified in this review.

#### Conclusion

According to the Community Guide's rules of evidence, available studies provide insufficient evidence to assess the effectiveness of provider education interventions when implemented alone. Evidence is insufficient because (1) few studies evaluated the effect on patient tobacco use cessation, and (2) studies that evaluated provider delivery of advice to quit demonstrated inconsistent results.

### Health Care Systems/Providers: Provider Reminder + Provider Education with or without Patient Education

#### Definition

Multicomponent strategies to increase tobacco use cessation include efforts to educate and to prompt providers to identify and to intervene with tobacco-using patients, as well as to provide supplementary educational materials when indicated. The components of this intervention are a provider reminder system and a provider education program, with or without patient education materials such as self-help cessation manuals.

#### Background

A multicomponent intervention can provide an integrated strategy to increase and improve tobacco use cessation by patients. These strategies can educate, motivate, and prompt providers to increase and improve their interaction with tobacco-using patients. These strategies can also improve patient cessation by increasing knowledge and motivation to quit and to remain abstinent. The multicomponent interventions evaluated in this section include at least one component directed at providers.

#### Review of evidence: effectiveness

Our search identified a total of 37 studies regarding the effectiveness of multicomponent health care system interventions in reducing tobacco use among patients. ^302, ^ ^307, ^ ^314, ^ ^320, ^ ^326, ^ ^328, ^ ^329, ^ ^334, ^ ^335, ^ ^336, ^ ^337, ^ ^338, ^ ^339, ^ ^340, ^ ^341, ^ ^342, ^ ^343, ^ ^344, ^ ^345, ^ ^346, ^ ^347, ^ ^348, ^ ^349, ^ ^350, ^ ^351, ^ ^352, ^ ^353, ^ ^354, ^ ^355, ^ ^356, ^ ^357, ^ ^358, ^ ^359, ^ ^360, ^ ^361, ^ ^362, ^ ^363^ Fifteen additional papers provided information on an already-included study. ^364, ^ ^365, ^ ^366, ^ ^367, ^ ^368, ^ ^369, ^ ^370, ^ ^371, ^ ^372, ^ ^373, ^ ^374, ^ ^375, ^ ^376, ^ ^377, ^ ^378^ Two studies with limited quality of execution ^328, ^ ^334^ and four studies with least suitable study designs ^345, ^ ^350, ^ ^355, ^ ^360^ were not included in the body of evidence. Details of the 31 qualifying studies are available at the website: www.thecommunityguide.org.

Twenty-one studies included at minimum the combination of a provider reminder system and a provider education program. ^302, ^ ^307, ^ ^314, ^ ^320, ^ ^326, ^ ^329, ^ ^335, ^ ^336, ^ ^337, ^ ^338, ^ ^339, ^ ^343, ^ ^344, ^ ^347, ^ ^348, ^ ^349, ^ ^352, ^ ^356, ^ ^357, ^ ^358, ^ ^361^ An additional component, patient education materials, was provided in 14 of these studies. ^314, ^ ^337, ^ ^338, ^ ^339, ^ ^343, ^ ^344, ^ ^347, ^ ^348, ^ ^349, ^ ^352, ^ ^356, ^ ^357, ^ ^358, ^ ^361^ One study measured changes in adolescent tobacco use initiation and is not considered further in this section. ^344^ Three studies evaluated a provider reminder system combined with other interventions without a provider education program. ^354, ^ ^359, ^ ^363^ Seven studies evaluated a provider education component combined with a patient education program without a provider reminder system. ^340, ^ ^341, ^ ^342, ^ ^346, ^ ^351, ^ ^353, ^ ^362^

The 20 qualifying studies, evaluating the effectiveness of a multicomponent intervention containing a minimum of a provider reminder system and a provider education program, reported 15 measurements regarding provider advice to quit and 14 measurements regarding patient tobacco use cessation (Figure 5). Overall, the absolute percentage differences in patient receipt of provider advice to quit ranged from +5.2 to +60 percentage points (median, +20 percentage points). In follow-up periods that ranged from 5 weeks to 12 months (median, 10 months) the absolute percentage differences in patient tobacco use cessation ranged from -1.0 to +25.9 percentage points (median, +4.7 percentage points).

Figure 5. Percentage point change in tobacco use cessation attributable to multicomponent interventions (minimum of a provider reminder and provider education components) from studies that qualified for inclusion in this review

A subset of 7 studies evaluated the minimum combination of a provider reminder system and a provider education program. ^302, ^ ^307, ^ ^320, ^ ^326, ^ ^329, ^ ^335, ^ ^336^ These studies provided 6 measurements of differences in provider advice to quit and 4 measurements of patient tobacco use cessation. The absolute percentage differences reported ranged from +6 to +39 percentage points (median, +12.5 percentage points) for provider advice to quit and -0.3 to +6.4 percentage points (median, +4.5 percentage points) for patient tobacco use cessation.

A subset of 13 studies evaluated interventions that included patient education materials combined with a provider reminder system and a provider education program. ^314, ^ ^337, ^ ^338, ^ ^339, ^ ^343, ^ ^347, ^ ^348, ^ ^349, ^ ^352, ^ ^356, ^ ^357, ^ ^358, ^ ^361^ These studies provided 9 measurements of provider advice to quit and 10 measurements of patient tobacco use cessation. The absolute percentage differences reported ranged from +5.2 to +60 percentage points (median, +22 percentage points) for provider advice to quit, and from -1 to +25.9 percentage points (median, +5.7 percentage points) for patient cessation.

Of the remaining studies, 3 included provider reminders and patient education without a provider education program. ^354, ^ ^359, ^ ^363^ These studies reported 3 measurements of differences in patient tobacco use cessation. The absolute percentage differences ranged from -0.6 to +5.2 percentage points (median, +1.2 percentage points) in follow-up periods of 6-12 months.

Seven studies evaluated combinations that included a provider education program without a provider reminder system. ^340, ^ ^341, ^ ^342, ^ ^346, ^ ^351, ^ ^353, ^ ^362^ These studies reported 5 measurements of differences in patient tobacco use cessation. Absolute percentage differences in cessation ranged from -1.5 to +4.6 percentage points (median, +0.5 percentage points) in follow-up periods of 6-12 months. ^340, ^ ^341, ^ ^342, ^ ^346, ^ ^362^ Only three studies measured changes in receipt of provider advice to quit (absolute percentage changes of +14.6, ^346^ -9, ^342^ and +22.7 ^362^ percentage points.

#### Review of evidence: applicability

The same body of evidence used in the assessment of effectiveness was used to assess the applicability of these interventions to different settings, populations, and forms of tobacco. The 21 studies of multicomponent interventions that included at least a provider education program and a provider reminder system were conducted in a variety of health care settings including HMOs, ^314, ^ ^339, ^ ^352, ^ ^356^ private practices, ^302, ^ ^337, ^ ^338, ^ ^347, ^ ^348, ^ ^349, ^ ^357, ^ ^358^ academic health care centers, ^307, ^ ^329, ^ ^348, ^ ^351^ physician training programs, ^307, ^ ^320, ^ ^326, ^ ^335, ^ ^343^ and public health clinics. ^361^ Studies were implemented in a variety of provider populations including primary care, ^307, ^ ^337, ^ ^347, ^ ^348, ^ ^349^ internal medicine, ^302, ^ ^314, ^ ^338, ^ ^339^ family medicine, ^302, ^ ^320, ^ ^326, ^ ^358^ obstetric care providers, ^329, ^ ^343, ^ ^352^ pediatricians, ^357^ and dental care providers. ^336, ^ ^344, ^ ^356^ One study focused on reducing use of smokeless tobacco. ^356^

#### Review of evidence: other positive or negative effects

Provider reminder systems have included prompts for other important preventive services. No other positive or negative effects were identified in this review.

#### Review of evidence: economic

No economic evaluations reporting on cost, cost-effectiveness, cost-benefit, or cost utility were identified in this review.

#### Barriers to intervention implementation

Administrative burden is a potential barrier to the implementation of provider reminder systems.

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence demonstrates that multicomponent health care system interventions that include a minimum of a provider reminder system and a provider education program are effective in increasing both provider delivery of advice to quit and patient tobacco use cessation. Additional effectiveness was demonstrated by studies that also included patient education, such as self-help cessation materials.

### Health Care Systems/Providers: Provider Feedback

#### Definition

Feedback interventions use retrospective assessment of provider performance in the identification of patient tobacco use status and/or the delivery of advice to quit, to inform and motivate providers. Techniques of assessment include chart reviews or the use of computerized records. Assessment and feedback interventions can be combined with other activities, such as provider reminders and provider education, and these combinations are considered in this section.

#### Background

Provider assessment and feedback can motivate providers to increase and improve their delivery of effective provider interactions with patients, such as advice to quit. Evaluation of provider assessment and feedback is timely because (1) clinical information systems are improving and are increasingly common; (2) effective cessation therapies are available and increasing provider interactions with tobacco-using patients could increase the use of these therapies; and (3) quality assurance approaches such as the Health-plan Employer Data and Information Set (HEDIS) are being used more often.

#### Review of evidence: effectiveness

Our search identified five studies evaluating the effectiveness of provider assessment and feedback interventions on provider behaviors with tobacco-using patients. ^379, ^ ^380, ^ ^381, ^ ^382, ^ ^383^ One study with limited quality of execution ^379^ and one study with a least-suitable study design ^380^ were not included in the evaluation of effectiveness. Details of the three qualifying studies are provided at the website: www.thecommunityguide.org.

A provider assessment and feedback program was evaluated alone in one study, ^381^ and in combination with other components in two studies including a provider education program, ^382, ^ ^383^ and a provider reminder flowsheet. ^382^ In all three studies, provider documentation or recognition of a patient's tobacco use status was only one of several preventive care practices for which assessment and feedback was provided (range, 3-26 items). Only one study used a computer system to collect information and enable providers to obtain feedback information. ^383^

None of the qualifying studies attempted to measure changes in provider delivery of advice to quit or patient tobacco use behaviors. The three qualifying studies provided three measurements of effectiveness in increasing provider recognition of patient tobacco use status. In study periods that ranged from 3 months to 6 years, the absolute percentage improvements in provider recognition of patient tobacco use status ranged from +13 to +39 percentage points (median, +21 percentage points).

#### Review of evidence: other positive or negative effects

Implementation of a provider assessment and feedback program increased provider delivery of other preventive care practices in these studies. ^381, ^ ^382^ No other positive or negative effects were identified in this review.

#### Conclusion

According to the Community Guide's rules of evidence, the available studies provided insufficient evidence to assess the effectiveness of provider assessment and feedback interventions in increasing either provider delivery of advice to quit or patient tobacco use cessation. Evidence is insufficient because the small number of available studies did not provide measurements on the outcomes required for an evaluation of effectiveness in this review (such as increasing provider delivery of advice to quit, or patient tobacco use cessation).

### Health Care Systems/Providers: Reducing Patient Out-of-pocket Costs for Effective Cessation Therapies

#### Definition

This intervention includes efforts to reduce the financial barriers to patient use of effective cessation therapies such as nicotine replacement, ^14^ other pharmacologic therapy, ^14^ and/or behavioral therapies such as cessation groups. ^14^

#### Background

Reducing out-of-pocket costs for effective cessation therapies has as its objectives: (1) to increase use of effective therapies; (2) to increase the number of persons who attempt to quit; and (3) to increase the number of persons who make successful cessation efforts.

#### Review of evidence: effectiveness

Our search identified five studies regarding the effectiveness of reducing patient out-of-pocket costs for effective tobacco cessation therapies. ^384, ^ ^385, ^ ^386, ^ ^387, ^ ^388^ All five studies were of fair quality of execution and greatest or moderate suitability of study design and were included in the evaluation of effectiveness. Details of the qualifying studies are available at the website: www.thecommunityguide.org.

All five studies evaluated interventions that reduced or eliminated patient costs for nicotine gum, ^384, ^ ^386, ^ ^387^ or nicotine replacement. ^385, ^ ^388^ In two studies, nicotine gum or replacement were provided as part of, ^384^ or in addition to, ^385^ a behavioral program. Access to a behavioral program was provided but rarely used in a third study. ^388^ In three studies, nicotine gum or nicotine replacement was provided free of charge to participants in the intervention group. ^384, ^ ^386, ^ ^388^ In one study, the out-of-pocket costs of the combination of behavioral program and nicotine replacement were $52.50 for comparison group patients and $10 for intervention group patients. ^385^

One study conducted in an HMO setting reported significant differences in the use of nicotine gum (measured in pieces of gum per user) by the level of drug co-payment, but the results could not be meaningfully expressed as a percentage point difference. ^387^ The remaining four studies ^384, ^ ^385, ^ ^386, ^ ^388^ provided four measurements of differences in use of cessation therapies and four measurements of differences in tobacco use cessation among study populations of recruited smokers ^384, ^ ^386, ^ ^388^ or among a general patient population. ^385^

All four studies observed increases in the use of cessation therapies. In three studies, the absolute percentage difference reported ranged from +6.5 to +28 percentage points (median +7 percentage points). ^384, ^ ^385, ^ ^386 ^ In one study, the difference in use was reported as an adjusted odds ratio of 2.26 (95% CI 1.60, 3.19). ^388^

All four studies also observed increases in tobacco use cessation, either measured as differences in the observed cessation rates ^384, ^ ^386, ^ ^388^ or as differences in the overall rates of cessation calculated for the study population. ^385^ In follow-up periods that ranged from 6 to 12 months (median, 9 months), absolute percentage differences in cessation ranged from +2.1 to +11 percentage points (median, +7.8 percentage points). In addition, one study reported an adjusted odds ratio for cessation of 1.63 (95% CI 1.14, 2.35). ^388^

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings and populations. All of these studies were conducted in the United States. Studies were conducted in several settings, including HMOs, ^385, ^ ^387, ^ ^388^ private practices, ^386^ and a Department of Defense hospital. ^384^ Studies were conducted in rural ^386^ and mixed rural-urban settings. ^385, ^ ^388^ One study was conducted among a low-income population. ^386^

#### Review of evidence: other positive or negative effects

One study observed an increase in the extended use of nicotine gum beyond the recommended duration (4 months). ^386^ No other potential benefits or harms were identified in this review

#### Review of evidence: economic

Of two studies reviewed, ^385, ^ ^386^ one was conducted in Washington state and reported program cost per quitter. ^385^ This study was conducted in a health care setting for employees enrolled in a health plan. The intervention consisted of insurance coverage for patients in a behavioral program that included nicotine replacement, with a 12-month follow-up. There were four types of insurance coverage, which differed according to the user's out-of-pocket-costs: (1) a 50 % copayment for the behavioral program and the usual $5 copayment per prescription for nicotine replacement therapy (standard coverage); (2) a 50% copayment for both the behavioral program and nicotine-replacement therapy (reduced coverage); (3) no copayment for the behavioral program but a 50% copayment for nicotine-replacement therapy (flipped coverage), and; (4) no copayment for the behavioral program and the usual $5 copayment per prescription for nicotine replacement therapy (full coverage). Costs measured included drugs, personnel, and cost of the behavioral program. Development, marketing, and implementation of the coverage plan were not included in the analysis. The adjusted program costs per quitter were $135, $141, $149, and $195 for standard, reduced, flipped, and full coverage, respectively. This study was classified as good, based on the quality assessment criteria used in the Community Guide. ^90^

The second study was a cost-benefit analysis conducted in Vermont, ^386^ reporting net benefit. This study was conducted at a rural family practice clinic with low-income patients. The intervention consisted of brief physician advice and a prescription for free nicotine gum, with a 6-month follow-up. Costs measured included physician time, nicotine gum, smoking cessation booklets, and patient time. Development, promotion, and evaluation costs were not included. The adjusted quit rate for the intervention group was 9.4%. When costs and benefits from averted illness were compared, the intervention was shown to be cost-saving. This study was classified as satisfactory, based on the quality assessment criteria used in the Community Guide. ^90^ (See also Appendix C, Interpreting the Economic Data.)

#### Barriers to intervention implementation

Potential barriers to increased use of effective cessation therapies are coverage requirements that tie pharmacotherapy to behavioral therapy interventions. Recent reviews have identified each strategy as effective alone. ^14^ These combinations demonstrate a higher cost-effectiveness, ^389^ but also limit use of effective therapies for smokers who are unwilling to participate in the behavioral program. These barriers might be reduced by including proactive telephone counseling as a behavioral therapy option. ^390^

#### Conclusion

According to the Community Guide's rules of evidence, sufficient scientific evidence demonstrates that reducing out-of-pocket costs for effective cessation therapies increases both use of the effective therapy and patient tobacco use cessation.

### Multicomponent Interventions Including Patient Telephone Support

#### Definition

Telephone support interventions provide tobacco product users with cessation counseling or assistance in initiating and/or maintaining abstinence. Telephone support can be reactive (tobacco user initiates contact) or proactive (provider initiates contact or user initiates contact with provider follow-up). Techniques for delivery of telephone support include the use of trained counselors, health care providers, or taped messages in single or multiple sessions. Telephone support sessions usually follow a standardized protocol for providing advice and counseling. The telephone support component is usually combined with other interventions, such as patient education materials, individual or group cessation counseling, or nicotine replacement therapies.

#### Background

Telephone contact can increase motivation to tobacco users to attempt to quit, and can provide support and assistance to recent quitters to reduce relapses. When implemented in a community setting, the telephone component typically provides access to cessation information such as self-help materials and available local resources (such as group sessions), and may provide counseling and motivation sessions. When implemented in a clinical setting, telephone follow-up calls usually support other clinical cessation interventions such as provider counseling, group cessation sessions, or nicotine replacement or other therapies.

#### Review of evidence: effectiveness

Our search identified 39 studies regarding the effectiveness of telephone cessation support. ^24, ^ ^232, ^ ^277, ^ ^314, ^ ^343, ^ ^351, ^ ^354, ^ ^355, ^ ^356, ^ ^361, ^ ^363, ^ ^391, ^ ^392, ^ ^393, ^ ^394, ^ ^395, ^ ^396, ^ ^397, ^ ^398, ^ ^399, ^ ^400, ^ ^401, ^ ^402, ^ ^403, ^ ^404, ^ ^405, ^ ^406, ^ ^407, ^ ^408, ^ ^409, ^ ^410, ^ ^411, ^ ^412, ^ ^413, ^ ^414, ^ ^415, ^ ^416, ^ ^417, ^ ^418^ Sixteen additional papers provided information on an already-included study. ^365, ^ ^366, ^ ^367, ^ ^370, ^ ^371, ^ ^372, ^ ^376, ^ ^377, ^ ^378, ^ ^419, ^ ^420, ^ ^421, ^ ^422, ^ ^423, ^ ^424, ^ ^425^ Four studies with limited quality of execution, ^391, ^ ^394, ^ ^396^ ^411^ and three studies with least suitable study designs, ^24, ^ ^232, ^ ^355^ were not included in the body of evidence. Details of the 32 qualifying studies are available at the website: www.thecommunityguide.org.

In all of the qualifying studies, telephone support was coordinated with additional interventions including patient education (29 studies), ^277, ^ ^343, ^ ^354, ^ ^356, ^ ^361, ^ ^363, ^ ^392, ^ ^393, ^ ^395, ^ ^397, ^ ^398, ^ ^399, ^ ^401, ^ ^402, ^ ^403, ^ ^404, ^ ^405, ^ ^406, ^ ^407, ^ ^408, ^ ^409, ^ ^410, ^ ^412, ^ ^413, ^ ^414, ^ ^415, ^ ^416, ^ ^417, ^ ^418^ provider-delivered counseling (17 studies), ^314, ^ ^351, ^ ^354, ^ ^356, ^ ^361, ^ ^363, ^ ^392, ^ ^395, ^ ^397, ^ ^398, ^ ^402, ^ ^405, ^ ^410, ^ ^412, ^ ^413, ^ ^414, ^ ^416^ nicotine replacement (4 studies), ^401, ^ ^405, ^ ^413, ^ ^417^ a smoking cessation clinic (1 study), ^400^ and a televised cessation series (1 study). ^277^ The qualifying studies included evaluations of telephone support interventions that were proactive (27 studies), ^314, ^ ^343, ^ ^351, ^ ^354, ^ ^356, ^ ^361, ^ ^363, ^ ^392, ^ ^395, ^ ^397, ^ ^398, ^ ^399, ^ ^400, ^ ^401, ^ ^402, ^ ^403, ^ ^404, ^ ^405, ^ ^406, ^ ^409, ^ ^410, ^ ^412, ^ ^413, ^ ^414, ^ ^416, ^ ^417, ^ ^418^ or reactive (5 studies). ^277, ^ ^393, ^ ^407, ^ ^408, ^ ^415^

Thirty of the 32 qualifying studies reported a total of 31 measurements of differences in patient tobacco use cessation (Figure 6). ^277, ^ ^343, ^ ^351, ^ ^354, ^ ^356, ^ ^361, ^ ^363, ^ ^392, ^ ^393, ^ ^395, ^ ^397, ^ ^398, ^ ^399, ^ ^400, ^ ^401, ^ ^402, ^ ^403, ^ ^404, ^ ^405, ^ ^406, ^ ^407, ^ ^408, ^ ^409, ^ ^410, ^ ^412, ^ ^413, ^ ^414, ^ ^415, ^ ^416, ^ ^418^ In follow-up periods of 5 weeks to 34 months (median, 12 months), these studies reported absolute percentage differences in cessation ranging from -3.4 to +23 percentage points (median, +2.6 percentage points). Seven measurements from six studies that compared telephone support and patient education to patient education alone ^399, ^ ^403, ^ ^404, ^ ^406, ^ ^408, ^ ^418^ provided similar results with absolute percentage differences in continuous tobacco use cessation ranging from +0.9 to +6.3 percentage points (median, +2.4 percentage points). Five of these six studies evaluated proactive telephone support systems. The median relative percent difference in tobacco use cessation in these studies was +41%.

Figure 6. Percentage point change in tobacco use cessation attributable to multicomponent interventions that included telephone cessation support from studies that qualified for inclusion in this review

#### Review of evidence: applicability

The same body of evidence used to assess effectiveness was used to assess the applicability of these interventions to different settings and populations. Telephone cessation support interventions have been implemented nationwide, ^407^ statewide, ^418^ and in regions and cities. ^277, ^ ^399, ^ ^408, ^ ^409, ^ ^415^ Studies were conducted in a variety of health care settings including HMOs, ^314, ^ ^356, ^ ^363, ^ ^392, ^ ^401, ^ ^403, ^ ^404, ^ ^405, ^ ^406, ^ ^414, ^ ^415^ private practices, ^412^ public health clinics, ^361^ medical centers and hospitals, ^351, ^ ^354, ^ ^398, ^ ^402, ^ ^410, ^ ^412^ and resident training programs. ^343^ ^351^ Provider specialties included dentistry, ^356^ obstetrics, gynecology, and family planning, ^343, ^ ^361, ^ ^395, ^ ^397, ^ ^403, ^ ^404, ^ ^412^ primary care, ^314, ^ ^363, ^ ^392, ^ ^406^ family practice, ^351, ^ ^363^ and internal medicine. ^351, ^ ^363^ Patient populations included hospitalized smokers, ^354, ^ ^398, ^ ^402, ^ ^405, ^ ^413, ^ ^414^ veterans, ^413, ^ ^416^ pregnant women, ^343, ^ ^361, ^ ^395, ^ ^403, ^ ^412^ African-Americans, ^407^ and older (60+years) smokers. ^409^ One study focused on changing smokeless tobacco use. ^356^

#### Review of evidence: other positive or negative effects

No positive or negative effects of telephone cessation support interventions were identified in this review.

#### Review of evidence: economic

Five studies were reviewed. ^423, ^ ^426, ^ ^427, ^ ^428, ^ ^429^ Two studies reported program costs per quitter, ^427, ^ ^429^ and three studies ^423, ^ ^426, ^ ^428^ reported program costs per life-year saved ratios, which were converted to cost per QALY using preference weights reported by Fiscella and Franks. ^249^

Both studies reporting program costs per quitter evaluated interventions to increase tobacco use cessation among pregnant women. ^427, ^ ^429^ The first study was conducted in Southern California in an HMO setting. ^427^ The intervention consisted of a combined prenatal nutrition counseling and smoking cessation program aimed at reducing the incidence of low birthweight infants. The smoking cessation program consisted of an eight-week home correspondence program that included weekly telephone calls to an automated answering service. The absolute percentage change in smoking cessation was +12 percentage points, with a comparison group cessation rate of 38%. Costs included salaries, overhead, supplies, printing, phone, and postage. Adjusted program cost per quitter was $677. This study was classified as good, based on the quality assessment criteria used in the Community Guide. ^90^

The second study was a nationwide, modeled intervention in the United States. ^429^ It consisted of a single 15-minute counseling session conducted by a nonmedical counselor, instructional material, and two follow-up telephone calls. The absolute percentage change in cessation was +15 percentage points, modeled from earlier randomized trials of smoking cessation among pregnant women. Costs included instructional materials, staff time, overhead, and training. Adjusted program cost per quitter was $292. This study was classified as good, based on the quality assessment criteria used in the Community Guide. ^90^ The difference in program cost between the two studies can be explained by the fact that the first study looked at a comprehensive intervention using more resources. This study was classified as good, based on the quality assessment criteria used in the Community Guide. ^90^

Of the three studies reporting program costs in terms of life-years saved, two studies ^423^ ^426^ looked at interventions conducted in hospital settings with adult patients who smoked. One study was conducted at the Mayo Clinic in Minnesota, ^426^ and the second was conducted at HMO hospitals in Oregon and Washington. ^423^ The comparison group quit rates for the studies were 10.7% and 9.2 %, respectively. The absolute percentage changes were +12 percentage points and +4 percentage points, respectively. The Mayo clinic intervention consisted of two programs: an individual nicotine-dependency treatment program, and a relapse prevention program. The relapse prevention program included telephone follow-up calls, letters, and a mailed survey. The comparison was a group of patients with no program. Costs included personnel, supplies, telephone, drugs, and capital equipment. Adjusted program cost per QALY was $2,532. The HMO hospital intervention consisted of a 20-minute bedside counseling session, a video, self-help materials, and follow-up calls. Costs included program development, personnel, communications, and overhead. Adjusted program cost per QALY of this intervention was $1,248. In comparing the two studies, the Mayo clinic intervention had a higher program cost per QALY in spite of showing a higher net effect size. This was because programs costs of the Mayo clinic intervention included letters, surveys, and treatment for nicotine dependency in addition to counseling and telephone calls. These studies were classified as good, based on the quality assessment criteria used in the Community Guide. ^90^

The third study ^428^ was conducted at a Boston hospital with patients who had had an acute myocardial infarction. The modeled intervention consisted of nurse-managed smoking-cessation counseling including telephone support after discharge. The comparison group consisted of patients exposed to standard smoking cessation counseling designed for survivors of acute myocardial infarction. The comparison group had a quit rate of 45%. The absolute percentage change was +26 percentage points. Costs included were personnel and instructional materials. Time spent on the phone, follow-up time, program development, and training costs were not included. The adjusted program costs per QALY was $73. This study was classified as good, based on the quality assessment criteria used in the Community Guide. ^90^ (See also Appendix C, Interpreting the Economic Data.)

#### Barriers to intervention implementation

One paper identified in this review ^420^ reported extremely low utilization of a reactive telephone support line implemented in an HMO setting. Several studies identified in the evaluation of mass media campaigns ^215, ^ ^229, ^ ^231, ^ ^253^ observed significant increases in use of telephone cessation services when the mass media messages directed viewers to call for further information or support.

#### Conclusion

According to the Community Guide's rules of evidence, strong scientific evidence exists that telephone cessation support is effective in increasing tobacco use cessation when implemented with other interventions (e.g., other educational approaches and/or clinical therapies) in both clinical and community settings. The minimum intervention with sufficient evidence of effectiveness identified in this evaluation was proactive telephone support combined with patient cessation materials.

### Research Issues for Increasing Tobacco Use Cessation: Community-wide Strategies

#### Effectiveness

The effectiveness of increasing the unit price for tobacco products and mass media campaigns (when implemented with other interventions) is established. However, research issues regarding the effectiveness of these interventions remain.

- What intervention components contribute most to effectiveness of multicomponent interventions? What components contribute the least?
- What are the minimum and optimal requirements for the duration and intensity of mass media campaigns?
- What are the most effective combinations of messages for mass media campaigns?
- Do tobacco users respond differently to changes in product price that result from excise tax increases than to industry-induced increases?
- How long do the effects of a single excise tax increase last?

Because the effectiveness of mass media cessation series and smoking cessation contests has not been established, basic research questions remain.

- Are these interventions effective in increasing tobacco use cessation in the population?
- Do recruited tobacco users exposed to these interventions quit at a greater rate than recruited tobacco users not exposed to these interventions?
- What are the rates of participation in these interventions?

#### Applicability

The effectiveness of increasing the unit price and of mass media campaigns in reducing tobacco use in the population is established. However, identifying differences in the effectiveness of each intervention for specific subgroups of the population remains important.

- Do significant differences exist regarding the effectiveness of these interventions based on the level of scale (i.e., national, state, local) at which they are delivered?
- What are the effects of mass media campaigns among populations that differ by race and ethnicity?

#### Other positive or negative effects

Several potential negative effects of tobacco product price increases were reviewed in this evaluation. Although further research on the potential negative effects is warranted, evaluating the impact of potential positive effects of reductions in tobacco use should also be investigated, to provide a complete picture of the effects of state and federal excise tax increases.

- What are the effects of these interventions on reducing smoking-related fires? What are the effects on ETS exposure?
- What proportion of smokers substitute tobacco products and/or modify their smoking habits in response to an increase in tobacco product price? How much of the potential health benefit of a price increase is reduced by these behaviors? How can these potential problems be reduced?
- Do mass media campaigns focusing on tobacco have additional effects on other drug use?

#### Economic evaluations

The available economic information on mass media campaigns was limited. Considerable research is therefore warranted regarding the following questions:

- What are the costs of mass media campaigns, especially campaigns that achieve an effective intensity over an extended duration?
- How do the costs per additional quitter compare with other interventions intended to reduce tobacco use?
- What is the cost-benefit, cost-utility, or cost per illness averted of these interventions?

#### Barriers

Implementation of these interventions requires political action and support. Research issues generated in this review include:

- What components of successful legislative and referendum campaigns are most effective? What components are least effective?
- What information is most important in gaining public support for these interventions? In gaining legislative support?
- What are the most effective ways to maintain adequate funding levels for mass media campaigns?

### Research Issues for Increasing Tobacco Use Cessation: Health Care System-Level Strategies

#### Effectiveness

The effectiveness of recommended and strongly recommended interventions in this section (i.e., multicomponent provider reminder + provider education with or without patient education materials; provider reminder systems alone; multicomponent interventions including telephone cessation support; and reducing patient out-of-pocket costs for cessation) is established. However research issues regarding the effectiveness of these interventions remain.

- Which characteristics of provider-based interventions contribute to increased or decreased effectiveness?
- What are the least and most effective combinations of services in multicomponent interventions?
- What is the effect of provider reminder systems on patient tobacco use cessation when implemented alone?
- What is the relative effectiveness of provider reminders that focus on determination of patient tobacco use status versus reminders that prompt for delivery of advice to quit?
- How do content and method of delivery of provider reminders relate to effectiveness?
- Can reducing patient costs for effective cessation services increase the effectiveness of provider-based interventions?
- What is the most effective level of implementation for telephone cessation support services?
- Is the use and effectiveness of telephone cessation support increased when community and clinical cessation support programs are coordinated?

Because the effectiveness of two interventions (provider education when used alone, and provider feedback systems) has not been established, basic research questions remain. This is especially true for provider assessment and feedback systems for which the number of available studies was small.

- What are the effects of provider assessment and feedback interventions on provider delivery of advice to quit to tobacco-using patients? On patient tobacco use cessation?
- What is the effectiveness of HEDIS, as a form of assessment, feedback, and benchmarking, in improving patient receipt of advice to quit and patient tobacco use cessation? Does effectiveness vary by practice setting?
- What frequency, duration, and format of provider education efforts are required to obtain consistent improvements in provider performance and patient response?

#### Applicability

Each recommended and strongly recommended provider-based intervention should be applicable in most relevant target populations and settings. However, possible differences in the effectiveness of each intervention for specific subgroups of patient and provider populations could not be determined. Several questions regarding the applicability of these interventions in settings and populations other than those studied remain.

- Do provider-based interventions differ in effectiveness in different patient populations?
- Are provider-based interventions effective in increasing cessation or in reducing initiation in adolescent populations?
- Do significant differences exist regarding the effectiveness of these interventions based on the level of scale at which they are delivered?

#### Other positive or negative effects

With the exception of the use of provider reminder systems to prompt action on other preventive services, studies in this review did not report on other positive and negative effects of these interventions. Research on the following questions would be useful:

- Do provider-based interventions for tobacco use cessation interfere with office flow or efficiency? If so, how can this effect be minimized?
- Do provider-based interventions increase or decrease the delivery of other preventive services?

#### Economic evaluation

Available economic information was limited in this section. Considerable research is warranted regarding the following questions:

- What are the costs for provider-based interventions?
- What are the costs for patient-based interventions?
- How do the costs per additional quitter compare with other interventions intended to reduce tobacco use?
- What is the cost-benefit, cost-utility, or the cost per illness averted of these interventions?
- What is the cost-effectiveness for provider interventions targeting tobacco alone compared with provider interventions targeting multiple preventive services?

#### Barriers

Research questions regarding the potential barriers identified for the interventions evaluated in this section include:

- How can provider-based interventions that place minimal administrative burden on providers or systems be implemented?
- What information is needed to overcome potential barriers to the implementation of provider assessment and feedback interventions?
- What information is needed to overcome potential barriers to reducing patient out-of-pocket costs for effective cessation therapies?
- What is the effect on use of combining effective pharmacologic therapies and behavioral programs as a criterion for reimbursement? What is the impact on use and effectiveness if these cessation options are provided independently?

## Acknowledgements

* Consultants for the chapter on preventing tobacco use and exposure were Dileep G. Bal, M.D., California Department of Health Services, Sacramento, California; Anthony Biglan Ph.D., Oregon Research Institute, Eugene, Oregon; Patricia A. Buffler, Ph.D., M.P.H., University of California, Berkeley, California; Gregory Connolly, D.M.D., M.P.H., Massachusetts Tobacco Control Program, Boston, Massachusetts; K. Michael Cummings, Ph.D., M.P.H., Roswell Park Institute, Buffalo, New York; Michael C. Fiore, M.D., M.P.H., University of Wisconsin Medical School, Madison, Wisconsin; David W. Fleming, M.D., Centers for Disease Control and Prevention, Atlanta, GA; Sally Malek, M.P.H., North Carolina Department of Health, Raleigh, North Carolina; Patricia A, Mullen, Dr.P.H., University of Texas Health Sciences Center, Houston, Texas; Cheryl L. Perry, Ph.D., University of Minnesota, Minneapolis, Minnesota; John P. Pierce, Ph.D., University of California, San Diego, California; Helen H. Schauffler, Ph.D., University of California, Berkeley, California; Randy H. Schwartz, MSPH, Maine Bureau of Health, Augusta, Maine; Mitchell Zeller, American Legacy Foundation, Washington, DC.

We appreciate the contributions of the tobacco prevention evidence review team:

Coordination Team-JE Fielding, MD, MPH, MBA, Los Angeles Department of Health Services, University of California Los Angeles School of Public Health, University of California Los Angeles School of Medicine, Los Angeles, CA (Task Force member); PA Briss, MD; VG Carande-Kulis, MS, PhD; DP Hopkins, MD, MPH , Division of Prevention Research and Analytic Methods, Epidemiology Program Office, Centers for Disease Control and Prevention, Atlanta, GA (Guide Staff members); CG Husten, MD, MPH, TF Pechacek, PhD, Office on Smoking and Health, National Centers for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, GA; TJ Glynn, PhD, American Cancer Society, Washington, DC.

Consultation Team-DG Bal, MD, California Department of Health Services, Sacramento, CA; A Biglan, PhD, Oregon Research Institute, Eugene, OR; PA Buffler, PhD, MPH, University of California, Berkeley, CA (Task Force member); G Connolly, DMD, MPH, Massachusetts Tobacco Control Program, Boston, MA; KM Cummings, PhD, MPH, Roswell Park Institute, Buffalo, NY; MC Fiore, MD, MPH, University of Wisconsin Medical School, Madison, WI; DW Fleming, MD, Centers for Disease Control, Atlanta, GA (Task Force member); S Malek, MPH, North Carolina Department of Health, Raleigh, NC; PA Mullen, DrPH, University of Texas Health Sciences Center, Houston, TX (Task Force member); CL Perry, PhD, University of Minnesota, Minneapolis, MN; JP Pierce, PhD, University of California, San Diego, CA; HH Schauffler, PhD, University of California, Berkeley, CA; RH Schwartz, MSPH, Maine Bureau of Health, Augusta, ME; M Zeller, American Legacy Foundation, Washington, DC.

Evaluation Team-N Sharma MA, MPA, T Woollery, PhD, DJ Sharp, MD, DTMH, JW McKenna, MS, CG Husten, MD, MPH, Office on Smoking and Health, National Centers for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, GA; CJ Ricard, MPH, JR Harris, MD, MPH, Division of Prevention Research and Analytic Methods, Epidemiology Program Office, Centers for Disease Control and Prevention, Atlanta, GA.

Abstraction Team-JF Bond, MS, Roswell Park Cancer Center, Buffalo, NY; CD Archbald, MD, MPH, New York City Department of Health, New York, NY; BM Morissette, MPH, PhD, University of South Florida, Tampa, FL; JA Dake, MPH, University of Toledo, Toledo, OH; C Herrington, MPH, University of South Florida, Treasure Island, FL; NL Lee, BS, Johns Hopkins School of Public Health, Baltimore, MD; LM Tomich, MS, RD, Santa Clara, CA; Y Yousey, MS, RN, University of Colorado Health Sciences Center, Evergreen, CO.

Project Editor-KW Harris BA, Division of Prevention Research and Analytic Methods, Epidemiology Program Office, Centers for Disease Control and Prevention, Atlanta, GA.

## References

1 McGinnis JM, Foege WH. Actual causes of death in the United States. JAMA. 1993;270:2207-12. [pmid: 8411605].
2 National Cancer Institute (US) Smoking and Tobacco Control Program. Changes in cigarette related disease risks and their implication for prevention and control. Bethesda, MD: National Institutes of Health, National Cancer Institute, 1997. Smoking and Tobacco Control Monograph 8.
3 US Department of Health and Human Services. Reducing the health consequences of smoking: 25 years of progress. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, CDC, 1989. DHHS publication no. (CDC) 89-8411.
4 US Department of Health and Human Services. Reducing tobacco use: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, Office on Smoking and Health, 2000.
5 Centers for Disease Control and Prevention. Best practices for comprehensive tobacco control programs-August 1999. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1999.
6 Miller LS, Zhang X, Novotny T, Rice DP, Max W. State estimates of Medicaid expenditures attributable to cigarette smoking, fiscal year 1993. Public Health Rep. 1998;113:140-51. [pmid: 9719815].
7 California Environmental Protection Agency. Health effects of exposure to environmental tobacco smoke-Final report and appendices. Sacramento: California Environmental Protection Agency, Office of Environmental Health Hazard Assessment, 1997.
8 US Environmental Protection Agency. Respiratory health effects of passive smoking: Lung cancer and other disorders. Washington, DC: US Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, 1992. EPA/600/6-90/006F.
9 US Office on Smoking and Health. The health consequences of involuntary smoking. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, Centers for Disease Control, Center for Health Promotion and Education, Office on Smoking and Health, 1986. DHHS publication no. (CDC) 87-8398.
10 US Department of Health Education and Welfare. Smoking and health. Report of the Advisory Committee to the Surgeon General of the Public Health Service. Washington, DC: U.S. Department of Health, Education, and Welfare; Public Health Service, 1964. PHS publication no. 1103.
11 Warner KE, Murt HA. Premature deaths avoided by the antismoking campaign. Am J Public Health. 1983;73:672-7. [pmid: 6846675].
12 Centers for Disease Control and Prevention. Cigarette smoking among adults-United States, 1998. MMWR Morbidity & Mortality Weekly Report. 2000;49 (39):881-4. [pmid: 11055740].
13 US Department of Health and Human Services. Tobacco use among US racial/ethnic minority groups-African Americans, American Indians and Alaska Natives, Asian Americans and Pacific Islanders, and Hispanics: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1998.
14 Fiore MC, Bailey WC, Cohen SJ, et al. Treating tobacco use and dependence. http://www.surgeongeneral.gov/tobacco. Accessed on July 13, 2000.
15 National Institutes of Health. Tobacco and the clinician: Interventions for medical and dental practice. Washington, DC: US Department of Health and Human Services, Public Health Service, National Institutes of Health, 1994. NIH publication no. 94-3693.
16 US Department of Heath and Human Services. The health benefits of smoking cessation. A report of the Surgeon General. Rockville, MD: US Department of Heath and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1990. DHHS publication no. (CDC) 90-8416.
17 US Department of Health and Human Services. Preventing tobacco use among young people: A report of the Surgeon General. Atlanta, GA: US Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.
18 Centers for Disease Control and Prevention. Trends in cigarette smoking among high school students-United States, 1991-1999. MMWR Morbidity & Mortality Weekly Report. 2000;49 (33):755-8. [pmid: 11758644].
19 US Department of Health and Human Services. Healthy people 2010 (conference ed, in 2 vols). Washington, DC: US Department of Health and Human Services, 2000.
20 Burns DM, Axelrad R, Bal D, et al. Report of the Tobacco Policy Research Study Group on Smoke-Free Indoor Air Policies. Tob Control. 1992;1(suppl):S14-S18.
21 Fielding JE. Banning worksite smoking [editorial]. Am J Public Health. 1986;76:957-9. [pmid: 3728767].
22 Pierce JP, Naquin M, Gilpin E, Giovino G, Mills S, Marcus S. Smoking initiation in the United States: a role for worksite and college smoking bans. J Natl Cancer Inst. 1991;83:1009-13. [pmid: 2072406].
23 Abernathy T, O'Grady B, Dukeshire S. Changes in ETS following anti-smoking legislation. Can J Public Health. 1998;89:33-4. [pmid: 9524387].
24 Amos A, White DA, Elton RA. Is a telephone helpline of value to the workplace smoker?. Occup Med. 1995;45:234-8.
25 Andrews JJ. Reducing smoking in the hospital. An effective model program. Chest. 1983;84:206-9.
26 Baile WF, Gibertini M, Ulschak F, Snow-Antle S, Hann D. Impact of a hospital smoking ban: changes in tobacco use and employee attitudes. Addict Behav. 1991;16:419-26. [pmid: 1801566].
27 Batlle E, Boixet M, Agudo A, Almirall J, Salvador T. Tobacco prevention in hospitals: long-term follow-up of a smoking control programme [see comments]. British Journal of Addiction. 1991;86:709-17. [pmid: 1878621].
28 Becker DM, Conner HF, Waranch HR, et al. The impact of a total ban on smoking in the Johns Hopkins Children's Center. JAMA. 1989;262:799-802. [pmid: 2746836].
29 Biener L, Abrams DB, Follick MJ, Dean L. A comparative evaluation of a restrictive smoking policy in a general hospital. Am J Public Health. 1989;79:192-5. [pmid: 2913839].
30 Borland R, Owen N, Hocking B. Changes in smoking behaviour after a total workplace smoking ban. Aust J Public Health. 1991;15:130-4. [pmid: 1912055].
31 Borland R, Pierce JP, Burns DM, Gilpin E, Johnson M, Bal D. Protection from environmental tobacco smoke in California: The case for a smoke-free workplace. JAMA. 1992;268:749-52. [pmid: 1640575].
32 Brenner H, Mielck A. Smoking prohibition in the workplace and smoking cessation in the Federal Republic of Germany. Prev Med. 1992;21:252-61. [pmid: 1579559].
33 Brenner H, Fleischle B. Smoking regulations at the workplace and smoking behavior: a study from southern Germany. Prev Med. 1994;23:230-4. [pmid: 8047530].
34 Brigham J, Gross J, Stitzer ML, Felch LJ. Effects of a restricted work-site smoking policy on employees who smoke. Am J Public Health. 1994;84:773-8. [pmid: 8179047].
35 Broder I, Pilger C, Corey P. Environment and well-being before and following smoking ban in office building. Can J Public Health. 1993;84:254-8. [pmid: 8221499].
36 Brownson RC, Davis J, Jackson-Thompson J, Wilkerson J. Environmental tobacco smoke awareness and exposure: impact of a statewide clean indoor air law and the report of the US Environmental Protection Agency. Tob Control. 1995;4:132-8.
37 Burns DM, Shanks TG, Major JM, Gower KB, Shopland DR. Restrictions on smoking in the workplace. Bethesda, MD: National Institutes of Health, National Cancer Institute. In press, Smoking and Tobacco Control Monograph 12.
38 Centers for Disease Control. Evaluation of an employee smoking policy-Pueblo, Colorado, 1989-90. MMWR Morbidity & Mortality Weekly Report. 1990;39:673-6. [pmid: 2118984].
39 Daughton DM, Andrews CE, Orona CP, Patil KD, Rennard SI. Total indoor smoking ban and smoker behavior. Prev Med. 1992;21:670-6. [pmid: 1438113].
40 Eisner MD, Smith AK, Blanc PD. Bartenders' respiratory health after establishment of smoke-free bars and taverns. JAMA. 1998;280:1909-14. [pmid: 9851475].
41 Emont SL, Choi WS, Novotny TE, Giovino GA. Clean indoor air legislation, taxation, and smoking behavior in the United States: an ecological analysis. Tob Control. 1992;2:13-7.
42 Etter J, Ronchi A, Perneger TV. Short-term impact of a university based smoke free campaign. J Epidemiol Community Health. 1999;53:710-5. [pmid: 10656100].
43 Evans WN, Farrelly MC, Montgomery E. Do workplace smoking bans reduce smoking?. The American Economic Review. 1999;89:728-47.
44 Farkas AJ, Gilpin E, Distefan JM, Pierce JP. The effects of household and workplace smoking restrictions on quitting behaviors. Tob Control. 1999;8:261-5. [pmid: 10599569].
45 Farrelly MC, Evans WN, Sfekas A. The impact of workplace smoking bans: results from a national survey. Tob Control. 1999;8:272-7. [pmid: 10599571].
46 Glasgow RE, Cummings KM, Hyland A. Relationship of worksite smoking policy to changes in employee tobacco use: findings from COMMIT. Community Intervention Trial for Smoking Cessation. Tob Control. 1997;6 Suppl 2:S44-S48. [pmid: 9583652].
47 Gottlieb NH, Eriksen MP, Lovato CY, Weinstein RP, Green LW. Impact of a restrictive work site smoking policy on smoking behavior, attitudes, and norms. J Occup Med. 1990;32:16-23. [pmid: 2324839].
48 Hammond SK, Sorensen G, Youngstrom R, Ockene JK. Occupational exposure to environmental tobacco smoke. JAMA. 1995;274:956-60. [pmid: 7674526].
49 Hudzinski LG, Frohlich ED. One-year longitudinal study of a no-smoking policy in a medical institution [see comments]. Chest. 1990;97:1198-202. [pmid: 2331915].
50 Jeffery RW, Kelder SH, Forster JL, French SA, Lando HA, Baxter JE. Restrictive smoking policies in the workplace: effects on smoking prevalence and cigarette consumption. Prev Med. 1994;23:78-82. [pmid: 8016037].
51 Kinne S, Kristal AR, White E, Hunt J. Work-site smoking policies: their population impact in Washington State. Am J Public Health. 1993;83:1031-3. [pmid: 8328601].
52 Longo DR, Brownson RC, Johnson JC, et al. Hospital smoking bans and employee smoking behavior: Results of a national survey. JAMA. 1996;275:1252-7. [pmid: 8601957].
53 Marcus BH, Emmons K, Abrams DB, et al. Restrictive workplace smoking policies: impact on nonsmokers' tobacco exposure. J Public Health Policy. 1992;13:42-51. [pmid: 1629358].
54 Martin M, Fehrenbach A, Rosner R. Ban on smoking in industry. N Engl J Med. 1986;315:647-8. [pmid: 3736607].
55 Millar WJ. Evaluation of the impact of smoking restrictions in a government work setting. Can J Public Health. 1988;79:379-82. [pmid: 3179907].
56 Moskowitz J, Lin Z, Hudes E. The impact of workplace smoking ordinances in California on smoking cessation. Am J Public Health. 2000;90:757-61. [pmid: 10800425].
57 Mullooly JP, Schuman KL, Stevens VJ, Glasgow RE, Vogt TM. Smoking behavior and attitudes of employees of a large HMO before and after a work site ban on cigarette smoking. Public Health Rep. 1990;105:623-8. [pmid: 2124362].
58 Offord KP, Hurt RD, Berge KG, Frusti DK, Schmidt L. Effects of the implementation of a smoke-free policy in a medical center [see comments]. Chest. 1992;102:1531-6. [pmid: 1424878].
59 Olive KE, Ballard JA. Changes in employee smoking behavior after implementation of restrictive smoking policies. South Med J. 1996;89:699-706. [pmid: 8685757].
60 Owen N, Borland R. Delayed compensatory cigarette consumption after a workplace smoking ban. Tob Control. 1997;6:131-5. [pmid: 9291223].
61 Patten CA, Pierce JP, Cavin SW, Berry C, Kaplan R. Progress in protecting non-smokers from environmental tobacco smoke in California workplaces. Tob Control. 1995;4:139-44.
62 Patten CA, Gilpin E, Cavin SW, Pierce JP. Workplace smoking policy and changes in smoking behavior in California: a suggested association. Tob Control. 1995;4:36-41.
63 Paulozzi LJ, Spengler RF, Gower MA. An evaluation of the Vermont worksite smoking law. Public Health Rep. 1992;107:724-6. [pmid: 1454986].
64 Petersen LR, Helgerson SD, Gibbons CM, Calhoun CR, Ciacco KH, Pitchford KC. Employee smoking behavior changes and attitudes following a restrictive policy on worksite smoking in a large company. Public Health Rep. 1988;103:115-20. [pmid: 3128826].
65 Rigotti NA, Pikl BH, Cleary P, Dinger DE, Mulley AG. The impact of banning smoking on a hospital ward: Accepatance, compliance, air quality and smoking behavior. Clin Res. 1986;34.
66 Rosenstock IM, Stergachis A, Heaney C. Evaluation of smoking prohibition policy in a health maintenance organization. Am J Public Health. 1986;76:1014-5. [pmid: 3728757].
67 Scott CJ, Gerberich SG. Analysis of a smoking policy in the workplace. AAOHN Journal. 1989;37:265-73. [pmid: 2735977].
68 Sorensen G, Rigotti NA, Rosen A, Pinney J, Prible R. Employee knowledge and attitudes about a work-site nonsmoking policy: rationale for further smoking restrictions. J Occup Med. 1991;33:1125-30. [pmid: 1765852].
69 Sorensen G, Beder B, Prible CR, Pinney J. Reducing smoking at the workplace: implementing a smoking ban and hypnotherapy. J Occup Environ Med. 1995;37:453-60. [pmid: 7670901].
70 Stave GM, Jackson GW. Effect of a total work-site smoking ban on employee smoking and attitudes. J Occup Med. 1991;33:884-90. [pmid: 1941284].
71 Stephens T, Pederson LL, Koval JJ, Kim C. The relationship of cigarette prices and no-smoking bylaws to the prevalence of smoking in Canada. Am J Public Health. 1997;87:1519-21. [pmid: 9314807].
72 Stillman FA, Becker DM, Swank RT, et al. Ending smoking at the Johns Hopkins Medical Institutions. An evaluation of smoking prevalence and indoor air pollution. JAMA. 1990;264:1565-9. [pmid: 2395198].
73 Sussman S, Pentz MA, Hahn G. The relationship of a worksite no-smoking policy to employee smoking behavior and attitudes. Prog Clin Biol Res. 1990;339:119-31. [pmid: 2392419].
74 Tsushima WT, Shimizu AA. Effects of a no-smoking policy upon medical center employees. Int J Addict. 1991;26:23-8. [pmid: 2066171].
75 Wakefield MA, Wilson D, Owen N, Esterman A, Roberts L. Workplace smoking restrictions, occupational status, and reduced cigarette consumption. J Occup Med. 1992;34:693-7. [pmid: 1494961].
76 Willemsen MC, Meiger A, Jannink M. Applying a contingency model of strategic decision making to the implementation of smoking bans; a case study. Health Education Research. 1999;14:519-31. [pmid: 10557522].
77 Borland R, Chapman S, Owen N, Hill D. Effects of workplace smoking bans on cigarette consumption. Am J Public Health. 1990;80:178-80. [pmid: 2297062].
78 Biener L, Abrams DB, Emmons K, Follick MJ. Evaluating worksite smoking policies. Methodologic issues. New York State Journal of Medicine. 1989;89:5-10. [pmid: 2922139].
79 Moskowitz J, Lin Z, Hudes E. The impact of California's smoking ordinances on worksite smoking policy and exposure to environmental tobacco smoke. American Journal of Health Promotion. 1999;13:278-81. [pmid: 10538642].
80 Pierce JP, Shanks TG, Pertschuk M, et al. Do smoking ordiances protect non-smokers from environmental tobacco smoke at work?. Tob Control. 1994;3:15-20.
81 Woodruff TJ, Rosbrook B, Pierce J, Glantz SA. Lower levels of cigarette consumption found in smoke-free workplaces in California. Arch Intern Med. 1993;153:1485-93. [pmid: 8512439].
82 Mudarri DH. The costs and benefits of smoking restrictions: An assessment of the Smoke-Free Environment Act of 1993 (H.R. 3434). Government Document 1994; H.R. 3434, April 1994.
83 Bartosch W, Pope G. The economic effect of smoke-free restaurant policies on restaurant business in Massachusetts. Journal of Public Health Management Practice. 1999;5:53-62.
84 Centers for Disease Control and Prevention. Assessment of the Impact of a 100% Smoke-Free Ordinance on Restaurant Sales—West Lake Hills, Texas, 1992-1994. MMWR Morbidity & Mortality Weekly Report. 1995;44:370-2. [pmid: 7739510].
85 Glantz SA, Charlesworth A. Tourism and hotel revenues before and after passage of smoke-free restaurant ordinances. JAMA. 1999;281:1911-8. [pmid: 10349895].
86 Glantz SA, Smith LR. The effect of ordinances requiring smoke-free restaurants on restaurant sales [published errata appear in Am J Public Health 1996 Jun;86(6):790 and 1997 Oct;87(10):1729-30]. Am J Public Health. 1994;84:1081-5. [pmid: 8017529].
87 Glantz S, Smith L. The effect of ordinances requiring smoke-free restraunts and bars on revenues: a follow-up. Am J Public Health. 1997;87:1687-93. [pmid: 9357356].
88 Hyland A, Cummings KM, Nauenberg E. Analysis of taxable sales receipts: was New York City's smoke-free air bad for restaurant business?. Journal of Public Health Management Practice. 1999;5:14-21. [pmid: 10345508].
89 Sciacca J, Eckrem M. Effects of a city ordinance regulating smoking in restaurants and retail stores. J Community Health. 1993;18:175-82. [pmid: 8408748].
90 Carande-Kulis VG, Maciosek MV, Briss PA, et al. Methods for systematic reviews of economic evaluations for the Guide to Community Preventive Services. Am J Prev Med. 2000;18(1S):75-91. [pmid: 10806980].
91 Centers for Disease Control and Prevention. Preemptive State Tobacco-Control Laws - United States, 1982-1998. MMWR Morbidity & Mortality Weekly Report. 1999;47:1112-4. [pmid: 9921728].
92 Siegel M, Carol J, Jordan J, et al. Preemption in tobacco control: Review of an emerging public health problem. JAMA. 1997;278:858-63. [pmid: 9293996].
93 Ellis GA, Hobart RL, Reed DF. Overcoming a powerful tobacco lobby in enacting local smoking ordinances: the Contra Costa County experience. J Public Health Policy. 1996;17:28-46. [pmid: 8919958].
94 Ashley MJ, Ferrence R. Reducing children's exposure to environmental tobacco smoke in homes: issues and strategies. Tob Control. 1998;7:61-5. [pmid: 9706756].
95 Greenberg RA, Strecher VJ, Bauman KE, et al. Evaluation of a home-based intervention program to reduce infant passive smoking and lower respiratory illness. J Behav Med. 1994;17:273-90. [pmid: 7932681].
96 Borland R, Mullins R, Trotter L, White V. Trends in environmental tobacco smoke restrictions in the home in Victoria, Australia. Tob Control. 1999;8:266-71. [pmid: 10599570].
97 Hovell MF, Zakarian JM, Wahlgren DR, Matt GE. Reducing children's exposure to environmental tobacco smoke: the empirical evidence and directions for future research. Tob Control. 2000;9(Suppl II):ii40-ii47. [pmid: 10841590].
98 Lynch BS, Bonnie RJ, Institute of Medicine:Committee on Preventing Nicotine Addiction in Children and Youths. Overview: Growing up tobacco free. Preventing nicotine addiction in children and youths. Washington, DC: National Academy Press, 1994.
99 Chaloupka F, Warner K. The economics of smoking. In: Culyer AJ, Newhouse JP, eds. Handbook of Health Economics. Vol 1B. Amsterdam: Elsevier Science, 2000:1539-627.
100 Nicholl J. Tobacco tax initiatives to prevent tobacco use. Cancer. 1998;83:2666-79. [pmid: 9874375].
101 Centers for Disease Control and Prevention. Response to increases in cigarette prices by race/ethnicity, income, and age groups-United States, 1976-1993. MMWR Morbidity & Mortality Weekly Report. 1998;47:605-9. [pmid: 9699809].
102 Chaloupka FJ, Wechsler H. Price, tobacco control policies and smoking among young adults. Journal of Health Economics. 1997;16:359-73. [pmid: 10169306].
103 Chaloupka FJ, Pacula RL. Sex and race differences in young people's responsiveness to price and tobacco control policies. Tob Control. 1999;8:373-7. [pmid: 10629242].
104 Gruber, J. Youth smoking in the U.S.: Prices and policies. http://papers.nber.org/papers/w7506.
105 Lewit EM, Coate D, Grossman M. The effects of government regulation on teenage smoking. Journal of Political Economy. 1981;24:545-70.
106 Lewit EM, Hyland A, Kerrebrock N, Cummings KM. Price, public policy, and smoking in young people. Tob Control. 1997;6 Suppl 2:S17-S24. [pmid: 9583648].
107 Ohsfeldt RL, Boyle RG, Capilouto E. Effects of tobacco excise taxes on the use of smokeless tobacco products in the USA. Health Education. 1997;6:525-31.
108 Wasserman J, Manning WG, Newhouse JP, Winkler JD. The effects of excise taxes and regulations on cigarette smoking. Journal of Health Economics. 1991;10:43-64. [pmid: 10112149].
109 Chaloupka FJ, Grossman M. Price, tobacco control policies and youth smoking. National Bureau of Economic Research. 1996;Working Paper 5740:1-39.
110 Chaloupka FJ, Tauras JA, Grossman M. Public policy and youth smokeless tobacco use. Southern Economic Journal. 1997;64:503-16.
111 Ohsfeldt RL, Boyle RG. Tobacco excise taxes and rates of smokeless tobacco use in the US: an exploratory ecological analysis. Tob Control. 1994;3:316-23.
112 Koh HK. An analysis of the successful 1992 Massachusetts tobacco tax initiative. Tob Control. 1996;5:220-5. [pmid: 9035358].
113 Traynor MP, Glantz SA. California's tobacco tax initiative: the development and passage of Proposition 99. J Health Polit Policy Law. 1996;21:543-85. [pmid: 8784688].
114 Worden JK, Flynn BS. Effective use of mass media to prevent cigarette smoking [Editorial]. Journal of Public Health Management and Practice. 2000;6:vii-viii. [pmid: 10848475].
115 Bauman KE, LaPrelle J, Brown JD, Koch GG, Padgett CA. The influence of three mass media campaigns on variables related to adolescent cigarette smoking: results of a field experiment. Am J Public Health. 1991;81:597-604. [pmid: 2014859].
116 Centers for Disease Control and Prevention. Tobacco use among middle and high school students-Florida, 1998 and 1999. MMWR Morbidity & Mortality Weekly Report. 1999;48:248-53. [pmid: 10220252].
117 Flay BR, Hansen WB, Johnson CA, et al. Implementation effectiveness trial of a social influences smoking prevention program using schools and television. Health Education Research. 1987;2:385-400.
118 Flay BR, Miller TQ, Hedeker D, et al. The television, school, and family smoking prevention and cessation project. VIII. Student outcomes and mediating variables. Prev Med. 1995;24:29-40. [pmid: 7740012].
119 Flynn BS, Worden JK, Secker-Walker RH, Pirie PL, Badger GJ, Carpenter JH. Long-term responses of higher and lower risk youths to smoking prevention interventions. Prev Med. 1997;26:389-94. [pmid: 9144764].
120 Hafstad A, Straypedersen B, Langmark F. Use of provocative emotional appeals in a mass media campaign designed to prevent smoking among adolescents. European Journal of Public Health. 1997;7:122-7.
121 Johnson CA, Pentz MA, Weber MD, et al. Relative effectiveness of comprehensive community programming for drug abuse prevention with high-risk and low-risk adolescents. J Consult Clin Psychol. 1990;58:447-56. [pmid: 2212182].
122 Kaufman JS, Jason LA, Sawlski LM, Halpert JA. A comprehensive multi-media program to prevent smoking among black students. J Drug Educ. 1994;24:95-108. [pmid: 7931927].
123 Meister JS. Designing an effective statewide tobacco control program-Arizona. Cancer. 1998;83:2728-32. [pmid: 9874386].
124 Murray DM, Prokhorov AV, Harty KC. Effects of a statewide antismoking campaign on mass media messages and smoking beliefs. Prev Med. 1994;23:54-60. [pmid: 8016033].
125 Perry CL, Kelder SH, Murray DM, Klepp KI. Communitywide smoking prevention: long-term outcomes of the Minnesota Heart Health Program and the Class of 1989 Study. Am J Public Health. 1992;82:1210-6. [pmid: 1503159].
126 Seghers T, Foland S. Anti-tobacco media campaign for young people. Tob Control. 1998;7 Suppl:S29-S30 (discussion). [pmid: 10093194].
127 Siegel M, Biener L. The impact of an antismoking media campaign on progressions to established smoking: Results of a longitudinal youth study. Am J Public Health. 2000;90:1-7.
128 Vartiainen E, Paavola M, McAlister A, Puska P. Fifteen-year follow-up of smoking prevention effects in the North Karelia youth project. Am J Public Health. 1998;88:81-5. [pmid: 9584038].
129 Bauman KE, Brown JD, Bryan ES, Fisher LA, Padgett CA, Sweeney JM. Three mass media campaigns to prevent adolescent cigarette smoking. Prev Med. 1988;17:510-30. [pmid: 3237655].
130 Bauman KE, Padgett CA, Koch GG. A media-based campaign to encourage personal communication among adolescents about not smoking cigarettes: Participation, selection and consequences. Special Issue: Smoking. Health Education Research. 1989;4:35-44.
131 Brannon BR, Dent CW, Flay BR, et al. The television, school, and family project. V. The impact of curriculum delivery format on program acceptance. Prev Med. 1989;18:492-502. [pmid: 2798371].
132 Flay BR, Brannon BR, Johnson CA, et al. The television school and family smoking prevention and cessation project. 1. Theoretical basis and program development. Prev Med. 1988;17:585-607. [pmid: 3237658].
133 Florida Department of Health. Florida Tobacco Youth Survey. Available at www.state.fl.us/tobacco.
134 Flynn BS, Worden JK, Secker-Walker RH, Badger GJ, Geller BM, Costanza MC. Prevention of cigarette smoking through mass media intervention and school programs. Am J Public Health. 1992;82:827-34. [pmid: 1585963].
135 Flynn BS, Worden JK, Secker-Walker RH, et al. Mass media and school interventions for cigarette smoking prevention: effects 2 years after completion. Am J Public Health. 1994;84:1148-50. [pmid: 8017542].
136 Hafstad A, Aaro LE, Langmark F. Evaluation of an anti-smoking mass media campaign targeting adolescents: The role of affective responses and interpersonal communication. Health Education Research. 1996;11:29-38.
137 Hafstad A, Aaro LE. Activating interpersonal influence through provocative appeals - evaluation of a mass media-based antismoking campaign targeting adolescents. Health Communication. 1997;9:253-72.
138 Hafstad A, Aaro LE, Engeland A, Andersen A, Langmark F, Straypedersen B. Provocative appeals in anti-smoking mass media campaigns targeting adolescents - the accumulated effect of multiple exposures. Health Education Research. 1997;12:227-36. [pmid: 10168574].
139 MacKinnon DP, Johnson CA, Pentz MA, et al. Mediating mechanisms in a school-based drug prevention program: first-year effects of the Midwestern Prevention Project. Health Psychol. 1991;10:164-72. [pmid: 1879388].
140 Murray DM, Perry CL, Griffin G, et al. Results from a statewide approach to adolescent tobacco use prevention. Prev Med. 1992;21:449-72. [pmid: 1409487].
141 Pentz MA, MacKinnon DP, Flay BR, Hansen WB, Johnson CA, Dwyer JH. Primary prevention of chronic diseases in adolescence: effects of the Midwestern Prevention Project on tobacco use. Am J Epidemiol. 1989;130:713-24. [pmid: 2788994].
142 Pentz MA, MacKinnon DP, Dwyer JH, et al. Longitudinal effects of the midwestern prevention project on regular and experimental smoking in adolescents. Prev Med. 1989;18:304-21. [pmid: 2740299].
143 Pentz MA, Johnson A, Dwyer JH, MacKinnon DM, Hansen WB, Flay BR. A comprehensive community approach to adolescent drug abuse prevention: effects on cardiovascular disease risk behaviors. Ann Med. 1989;21:219-22. [pmid: 2765263].
144 Pentz MA, Trebow EA, Hansen WB, et al. Effects of program implementation on adolescent drug use behavior: The Midwestern Prevention Project (MPP). Evaluation Review. 1990;14:264-89.
145 Perry CL, Klepp KI, Sillers C. Community-wide strategies for cardiovascular health: The Minnesota Heart Health Program youth program. Special Issue: Smoking. Health Education Research. 1989;4:87-101.
146 Puska P, Vartiainen E, Pallonen U, et al. The North Karelia Youth Project. A community-based intervention study on CVD risk factors among 13- to 15-year-old children: study design and preliminary findings. Prev Med. 1981;10:133-48. [pmid: 7220498].
147 Puska P, Vartiainen E, Pallonen U, et al. The North Karelia youth project: evaluation of two years of intervention on health behavior and CVD risk factors among 13- to 15-year old children. Prev Med. 1982;11:550-70. [pmid: 7156063].
148 Secker-Walker RH, Worden JK, Holland RR, Flynn BS, Detsky AS. A mass media programme to prevent smoking among adolescents: costs and cost effectiveness. Tob Control. 1997;6:207-12. [pmid: 9396105].
149 Sussman S, Brannon BR, Flay BR, et al. The television, school, and family smoking prevention/cessation project. II. Formative evaluation of television segments by teenagers and parents-implications for parental involvement in drug education. Health Education Research. 1986;1:185-94.
150 Sussman S, Dent CW, Brannon BR, et al. The television, school and family smoking prevention/cessation project. IV. Controlling for program success expectancies across experimental and control conditions. Addict Behav. 1989;14:601-10. [pmid: 2618843].
151 Vartiainen E, Pallonen U, McAlister A, Koskela K, Puska P. Effect of two years of educational intervention on adolescent smoking (the North Karelia Youth Project). Bull World Health Organ. 1983;61:529-32. [pmid: 6603925].
152 Vartiainen E, Pallonen U, McAlister A, Koskela K, Puska P. Four-year follow-up results of the smoking prevention program in the North Karelia Youth Project. Prev Med. 1986;15:692-8. [pmid: 3797400].
153 Vartiainen E, Fallonen U, McAlister AL, Puska P. Eight-year follow-up results of an adolescent smoking prevention program: the North Karelia Youth Project. Am J Public Health. 1990;80:78-9. [pmid: 2293810].
154 Vartiainen E, Tossavainen K, Viri L, Niskanen E, Puska P. The North Karelia Youth Programs. Ann N Y Acad Sci. 1991;623:332-49. [pmid: 2042842].
155 Worden JK, Flynn BS, Geller BM, et al. Development of a smoking prevention mass media program using diagnostic and formative research. Prev Med. 1988;17:531-58. [pmid: 3237656].
156 Worden JK, Flynn BS, Solomon LJ, Secker-Walker RH, Badger GJ, Carpenter JH. Using mass media to prevent cigarette smoking among adolescent girls. Health Educ Q. 1996;23:453-68. [pmid: 8910024].
157 Levy DT, Friend K. Gauging the effects of mass media policies: what do we need to know?. Journal of Public Health Management and Practice. 2000;6:95-106. [pmid: 10848489].
158 Flewelling RL, Kenney E, Elder JP, Pierce J, Johnson M, Bal DG. First-year impact of the 1989 California cigarette tax increase on cigarette consumption [see comments]. Am J Public Health. 1992;82:867-9. [pmid: 1585966].
159 Glantz S. Changes in cigarette consumption, prices, and tobacco industry revenues associated with California's Proposition 99. Tob Control. 1993;2:311-4.
160 Hu TW, Bai J, Keeler TE, Barnett PG, Sung HY. The impact of California Proposition 99, a major anti-smoking law, on cigarette consumption. J Public Health Policy. 1994;15:26-36. [pmid: 8027359].
161 Hu TW, Sung HY, Keeler TE. Reducing cigarette consumption in California: tobacco taxes vs an anti-smoking media campaign. Am J Public Health. 1995;85:1218-22. [pmid: 7661228].
162 Hu TW, Ren QF, Keeler TE, Bartlett J. The demand for cigarettes in California and behavioural risk factors. Health Econ. 1995;4:7-14. [pmid: 7780529].
163 Keeler TE, Hu T, Barnett PG, Manning WG. Taxation, regulation, and addiction: a demand function for cigarettes based on time-series evidence. Journal of Health Economics. 1993;12:1-18. [pmid: 10126486].
164 Pierce JP, Gilpin E, Emery SL, White MM, Rosbrook B, Berry C. Has the California Tobacco Control Program Reduced Smoking?. JAMA. 1998;280:893-9. [pmid: 9739973].
165 Centers for Disease Control and Prevention. Cigarette smoking before and after an excise tax increase and an antismoking campaign-Massachusetts, 1990-1996. MMWR Morbidity & Mortality Weekly Report. 1996;45:966-70. [pmid: 8965795].
166 Centers for Disease Control and Prevention. Decline in cigarette consumption following implementation of a comprehensive tobacco prevention and education program-Oregon, 1996-1998. MMWR - Morbidity & Mortality Weekly Report. 1999;48:140-3. [pmid: 10077459].
167 Sung H, Hu T, Keeler TE. Cigarette taxation and demand: An empirical model. Contemporary Economic Policy. 1994;12:91-100.
168 Meier KJ, Licari MJ. The effect of cigarette taxes on cigarette consumption, 1955 through 1994. Am J Public Health. 1997;87:1126-30. [pmid: 9240101].
169 Evans WN, Ringel JS, Stech D. Tobacco taxes and public policy to discourage smoking. Tax policy and the economy. 1999;13:1-56.
170 Baltagi BH, Goel RK. Quasi-experimental price elasticities of cigarette demand and the bootlegging effect. American Agricultural Economics Association. 1987;69:750-4.
171 Barnett PG, Keeler TE, Hu T. Oligopoly structure and the incidence of cigarette excise taxes. Journal of Public Economics. 1995;57:457-70.
172 Becker GS, Grossman M, Murphy KM. An empirical analysis of cigarette addiction. American Economic Review. 1994;84:396-418.
173 Chaloupka F, Saffer H. Clean indoor air laws and the demand for cigarettes. Contemporary Policy Issues. 1992;10:72-83.
174 Evans WN, Farrelly MC. The compensating behavior of smokers: Taxes, tar, and nicotine. Rand Journal of Economics. 1998;29:578-95. [pmid: 11794360].
175 Jackson JD, Saba RP. Some limits on taxing sin: Cigarette taxation and health care finance. Southern Economic Journal 1997; 761-75.
176 Moore MJ. Death and tobacco taxes. Rand Journal of Economics. 1996;27:415-28.
177 Peterson DE, Zeger SL, Remington PL, Anderson HA. The effect of state cigarette tax increases on cigarette sales, 1955 to 1988. Am J Public Health. 1992;82:94-6. [pmid: 1536343].
178 Saba RP, Beard TR, Ekelund RB, Ressler RW. The demand for cigarette smuggling. Economic Inquiry. 1995;23:189-202.
179 Seldon BJ, Doroodian K. A simultaneous model of cigarette advertising: Effects on demand and industry response to public policy. Review of Economics and Statistics. 1989;71:673-7.
180 Seldon BJ, Boyd R. The stability of cigarette demand. Applied Economics. 1991;23:319-26.
181 Tegene A. Kalman filter and the demand for cigarettes. Applied Economics. 1991;23:1175-82.
182 Thursby JG, Thursby MC. Interstate cigarette bootlegging: Extent, revenue losses, and effects of federal intervention. National Bureau of Economic Research 1996; 2-29.
183 Tremblay CH, Tremblay VJ. The impact of cigarette advertising on consumer surplus, profit, and social welfare. Contemporary Economic Policy. 1995;13:113-24.
184 Goel RK, Morey MJ. The interdependence of cigarette and liquor demand. Southern Economic Journal. 1998;October:451-9.
185 Baltagi BH, Levin D. Estimating dynamic demand for cigarettes using panel data: the effects of bootlegging, taxation and advertising reconsidered. Review of Economics and Statistics. 1986;68:148-55.
186 Bishop JA, Yoo JH. Health scare, excise taxes and advertising ban in the cigarette demand and supply. Southern Economic Journal. 1985;52:402-11.
187 Chaloupka F. Clean indoor air laws, addiction, and cigarette smoking. Applied Economics. 1992;24:193-205.
188 Chaloupka FJ. Rational addictive behavior and cigarette smoking. Journal of Political Economy. 1991;99:722-42.
189 Douglas S, Hariharan G. The hazard of starting smoking: estimates from a split population duration model. Journal of Health Economics. 1994;13:213-30. [pmid: 10138026].
190 Fujii ET. The demand for cigarettes: further empirical evidence and its implications for public policy. Applied Economics. 1980;12:479-89.
191 Lewitt EM, Coate D. The potential for using excise taxes to reduce smoking. Journal of Health Economics. 1982;1:121-45. [pmid: 10263952].
192 Schneider L, Klein B, Murphy KM. Governmental regulation of cigarette health information. Journal of Law and Economics. 1981;24:575-612.
193 Young T. The demand for cigarettes: alternative specifications of Fujii's model. Applied Economics. 1983;15:203-11.
194 Galbraith JW, Kaiserman M. Taxation, smuggling and demand for cigarettes in Canada: Evidence from time-series data. Journal of Health Economics. 1997;16:287-301. [pmid: 10169302].
195 Hamilton VH, Levinton C, St-Pierre Y, Grimard F. The effect of tobacco tax cuts on cigarette smoking in Canada [see comments]. Can Med Assoc J. 1997;156:187-91. [pmid: 9012719].
196 Mummery WK, Hagen LC. Tobacco pricing, taxation, consumption and revenue: Alberta 1985-1995. Can J Public Health. 1996;87:314-6. [pmid: 8972965].
197 Jones A. UK demand for cigarettes 1954-1986, a double-hurdle approach. Journal of Health Economics. 1989;8:133-41. [pmid: 10293368].
198 Townsend J, Roderick P, Cooper J. Cigarette smoking by socioeconomic group, sex, and age: effects of price, income, and health publicity [see comments]. BMJ. 1994;309:923-7. [pmid: 7950662].
199 Townsend JL. Cigarette tax, economic welfare, and social class patterns of smoking. Applied Economics. 1987;19:355-65.
200 Worgotter GF, Kunze M. Cigarette prices and cigarette consumption in Austria, 1955-1983. New York State Journal of Medicine. 1986;86:478-9. [pmid: 3464863].
201 Pekurinen M. The demand for tobacco products in Finland. British Journal of Addiction. 1989;84:1183-92. [pmid: 2819275].
202 Leu R. The effects of cigarette price and anti-smoking publicity on cigarette consumption in Switzerland. Rev Epidemiol Sante Publique. 1979;27:359-62. [pmid: 538309].
203 Leu R. Anti-smoking publicity, taxation, and the demand for cigarettes. Journal of Health Economics. 1984;3:101-16. [pmid: 10268368].
204 Laugesen M, Meads C. Tobacco advertising restrictions, price, income and tobacco consumption in OECD countries, 1960-1986 [see comments]. British Journal of Addiction. 1991;86:1343-54. [pmid: 1751850].
205 Kaiserman MJ, Rogers B. Tobacco consumption declining faster in Canada than in the US. Am J Public Health. 1991;81:902-4. [pmid: 2053670].
206 Labeaga JM. Individual behaviour and tobacco consumption: a panel data approach. Health Econ. 1993;2:103-12. [pmid: 8261032].
207 Miller E. Taxes, cigarettes and the health of Maine citizens. Journal of the Maine Medical Association. 1977;68:58-62. [pmid: 401858].
208 Reekie WD. Consumers' surplus and the demand for cigarettes. Managerial and Decision Economics. 1994;15:223-34.
209 Laugesen M, Meads C. Advertising, price, income and publicity effects on weekly cigarette sales in New Zealand supermarkets [see comments]. British Journal of Addiction. 1991;86:83-9. [pmid: 2009401].
210 Advisory Commission on Intergovernmental Relations. Cigarette tax evasion: a second look. Washington, DC: Advisory Commission on Intergovernmental Relations, 1985.
211 Hamilton JL. The demand for cigarettes: Advertising, the health scare, and the cigarette advertising ban. The Review of Economics and Statistics. 1972;54:401-11.
212 Warner KE. Effects of the antismoking campaign: an update. Am J Public Health. 1989;79:144-51. [pmid: 2913831].
213 US Department of Health and Human Services. Strategies to control tobacco use in the United States: A blueprint for public health action in the 1990's. Bethesda, MD: US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute, 1991. NIH publication no. 92-3316.
214 Barber JJ, Grichting WL. Australia's media campaign against drug abuse. Int J Addict. 1990;25:693-708. [pmid: 2265870].
215 Boyd NR, Sutton C, Orleans CT, et al. Quit Today: A targeted communications campaign to increase use of the cancer information service by African American smokers. Prev Med. 1998;27 (5 Pt 2):S50-S60. [pmid: 9808824].
216 Campion P, Owen L, McNeill A, McGuire C. Evaluation of a mass media campaign on smoking and pregnancy. Addiction. 1994;89:1245-54. [pmid: 7804085].
217 Cummings KM, Sciandra R, Davis S, Rimer BK. Results of an antismoking media campaign utilizing the Cancer Information Service. J Natl Cancer Inst Monogr 1993; 113-8.
218 Fortmann SP, Taylor CB, Flora JA, Jatulis DE. Changes in adult cigarette smoking prevalence after 5 years of community health education: the Stanford Five-City Project. Am J Epidemiol. 1993;137:82-96. [pmid: 8434576].
219 Gredler B, Kunze M. Impact of a national campaign on smoking attitudes and patterns in Austria. International Journal of Health Education. 1981;24:271-9. [pmid: 7344374].
220 Jenkins CN, McPhee SJ, Le A, Pham GQ, Ha NT, Stewart S. The effectiveness of a media-led intervention to reduce smoking among Vietnamese-American men. Am J Public Health. 1997;87:1031-4. [pmid: 9224191].
221 Ledwith F. Immediate and delayed effects of postal advice on stopping smoking. Health Bull. 1984;42:332-44.
222 Luepker RV, Murray DM, Jacobs DJ, et al. Community education for cardiovascular disease prevention: risk factor changes in the Minnesota Heart Health Program. Am J Public Health. 1994;84:1383-93. [pmid: 8092360].
223 Marin G, Perez-Stable EJ. Effectiveness of disseminating culturally appropriate smoking-cessation information: Programa Latino Para Dejar de Fumar. J Natl Cancer Inst Monogr 1995; 155-63.
224 McAlister AL, Ramirez AG, Amezcua C, Pulley L, Stern MP, Mercado S. Smoking cessation in Texas-Mexico border communities: A quasi-experimental panel study. American Journal of Health Promotion. 1992;6:274-9. [pmid: 10148752].
225 McPhee SJ, Jenkins CN, Wong C, et al. Smoking cessation intervention among Vietnamese Americans: a controlled trial. Tob Control. 1997;4 (Suppl 1):S16-S24.
226 Meyer AJ. Skills training in a cardiovascular health education campaign. J Consult Clin Psychol. 1980;48:129-42. [pmid: 7365050].
227 Mogielnicki RP, Neslin S, Dulac J, Balestra D, Gillie E, Corson J. Tailored media can enhance the success of smoking cessation clinics. J Behav Med. 1986;9:141-61. [pmid: 3712426].
228 Mudde AN, de Vries H, Dolders MG. Evaluation of a Dutch community-based smoking cessation intervention. Prev Med. 1995;24:61-70. [pmid: 7740017].
229 Ossip-Klein DJ, Shapiro RM, Stiggins J. Freedom line: increasing utilization of a telephone support service for ex-smokers. Addict Behav. 1984;9:227-30. [pmid: 6741686].
230 Pierce JP, Macaskill P, Hill D. Long-term effectiveness of mass media led antismoking campaigns in Australia. Am J Public Health. 1990;80:565-9. [pmid: 2327533].
231 Pierce JP, Anderson DM, Romano RM, Meissner HI, Odenkirchen JC. Promoting smoking cessation in the United States: effect of public service announcements on the Cancer Information Service telephone line [see comments]. J Natl Cancer Inst. 1992;84:677-83. [pmid: 1569601].
232 Platt S, Tannahill A, Watson J, Fraser E. Effectiveness of antismoking telephone helpline: follow up survey. BMJ. 1997;314:1371-5. [pmid: 9161308].
233 Shuster GF, Utz SW, Merwin E. Implementation and outcomes of a community-based self-help smoking cessation program. J Community Health Nurs. 1996;13:187-98. [pmid: 8916608].
234 Vartiainen E, Puska P, Jousilahti P, Korhonen HJ, Tuomilehto J, Nissinen A. Twenty-year trends in coronary risk factors in north Karelia and in other areas of Finland. Int J Epidemiol. 1994;23:495-504. [pmid: 7960373].
235 Dwyer T, Pierce JP, Hannam CD, Burke N. Evaluation of the Sydney "Quit for Life" anti-smoking campaign. Part 2. Changes in smoking prevalende. Med J Aust. 1986;144:344-7. [pmid: 3485760].
236 Farquhar JW, Maccoby N, Wood PD, et al. Community education for cardiovascular health. Lancet. 1977;1:1192-5. [pmid: 68285].
237 Farquhar JW, Fortmann SP, Maccoby N, et al. The Stanford Five-City Project: design and methods. Am J Epidemiol. 1985;122:323-34. [pmid: 4014215].
238 Farquhar JW, Fortmann SP, Flora JA, et al. Effects of communitywide education on cardiovascular disease risk factors. The Stanford Five-City Project. JAMA. 1990;264:359-65.
239 Marin G, Marin BV, Perez-Stable EJ, Sabogal F, Otero-Sabogal R. Changes in information as a function of a culturally appropriate smoking cessation community intervention for Hispanics. Am J Community Psychol. 1990;18:847-64. [pmid: 2091458].
240 Perez-Stable EJ, Marin BV, Marin G. A comprehensive smoking cessation program for the San Francisco Bay area Latino community: Programa Latino para dejar de fumar. American Journal of Health Promotion. 1993;7:430-42. [pmid: 10146254].
241 Pierce JP, Dwyer T, Frape G, Chapman S, Chamberlain A, Burke N. Evaluation of the Sydney "Quit For Life" anti-smoking campaign. Part 1. Achievement of intermediate goals. Med J Aust. 1986;144:341-4. [pmid: 3959949].
242 Pierce JP, Burns DM, Berry C, et al. Reducing tobacco consumption in California: Proposition 99 seems to work [letter]. JAMA. 1991;265:1257-8. [pmid: 1995967].
243 Popham WJ, Potter LD, Hetrick MA, Muthen LK, Duerr JM, Johnson MD. Effectiveness of the California 1990-1991 tobacco education media campaign [see comments]. Am J Prev Med. 1994;10:319-26. [pmid: 7880550].
244 Puska P, Wiio J, McAlister A, et al. Planned use of mass media in national health promotion: the "Keys to Health" TV program in 1982 in Finland. Can J Public Health. 1985;76:336-42. [pmid: 4084887].
245 Jacobs Jr. DR, Luepker RV, Mittelmark MB, et al. Community-wide prevention strategies: Evaluation design of the Minnesota Heart Health Program. Journal of Chronic Diseases. 1986;39:775-88. [pmid: 3760106].
246 Marin BV, Perez-Stable EJ, Marin G, Hauck WW. Effects of a community intervention to change smoking behavior among Hispanics. Am J Prev Med. 1994;10:340-7. [pmid: 7880553].
247 Mudde AN, de Vries H, Strecher VJ. Cost-effectiveness of smoking cessation modalities: comparing apples with oranges?. Prev Med. 1996;25:708-16. [pmid: 8936573].
248 Ratcliffe J, Cairns J, Platt S. Cost effectiveness of a mass media-led anti-smoking campaign in Scotland. Tob Control. 1997;6:104-10. [pmid: 9291218].
249 Fiscella K, Franks P. Cost-effectiveness of the transdermal nicotine patch as an adjunct to physicians' smoking cessation counseling [see comments]. JAMA. 1996;275:1247-51. [pmid: 8601956].
250 Novotny TE, Siegel MB. California's tobacco control saga. Health Aff. 1996;15:58-72.
251 Begay ME, Traynor M, Glantz SA. The tobacco industry, state politics, and tobacco education in California. Am J Public Health. 1993;83:1214-21. [pmid: 8362994].
252 Ben-Sira Z. The health promoting function of mass media and reference groups: motivating or reinforcing of behavior change. Soc Sci Med. 1982;16:825-34. [pmid: 7101000].
253 Cummings KM, Sciandra R, Markello S. Impact of a newspaper mediated quit smoking program. Am J Public Health. 1987;77:1452-3. [pmid: 3661801].
254 Danaher BG, Berkanovic E, Gerber B. Mass media based health behavior change: televised smoking cessation program. Addict Behav. 1984;9:245-53. [pmid: 6437149].
255 Harvey M, Tuffin A, Tuffin K. An evaluation of a community based antismoking campaign. N Z Med J. 1990;103:243-5. [pmid: 2342707].
256 Jason LA, Tait E, Goodman D, Buckenberger L, Gruder CL. Effects of a televised smoking cessation intervention among low-income and minority smokers. Am J Community Psychol. 1988;16:863-76. [pmid: 3223489].
257 Korhonen HJ, Niemensivu H, Piha T, et al. National TV smoking cessation program and contest in Finland. Prev Med. 1992;21:74-87. [pmid: 1738770].
258 Leroux RS, Miller ME. Electronic media-based smoking cessation clinic, in the USA. Hygie. 1983;2:23-37. [pmid: 6873949].
259 Millar WJ, Naegele BE. Time to quit: community involvement in smoking cessation. Can J Public Health. 1987;78:109-14. [pmid: 2438026].
260 Mudde AN, de Vries H. The reach and effectiveness of a national mass media-led smoking cessation campaign in The Netherlands. Am J Public Health. 1999;89:346-50. [pmid: 10076483].
261 Ryan B, Coffin K, Smillie C, Porter K. Smoking cessation in Nova Scotia: results of the Time to Quit program. Can J Public Health. 1990;81:166-7. [pmid: 2331658].
262 Salina D, Jason LA, Hedeker D, et al. A follow-up of a media-based, worksite smoking cessation program. Am J Community Psychol. 1994;22:257-71. [pmid: 7977180].
263 Sallis JF, Flora JA, Fortmann SP, Taylor CB, Maccoby N. Mediated smoking cessation programs in the Stanford Five-City Project. Addict Behav. 1985;10:441-3. [pmid: 4091078].
264 Sutton S, Hallett R. Randomized trial of brief individual treatment for smoking using nicotine chewing gum in a workplace setting. Am J Public Health. 1987;77:1210-1. [pmid: 3303976].
265 Thompson B. Characteristics and predictors of participation and success in a televised smoking cessation activity. American Journal of Health Promotion. 1994;8:175-7. [pmid: 10147258].
266 Valois RF, Adams KG, Kammermann SK. One-year evaluation results from CableQuit: a community cable television smoking cessation pilot program. J Behav Med. 1996;19:479-99. [pmid: 8904730].
267 Warnecke RB, Langenberg P, Wong SC, Flay BR, Cook TD. The second Chicago televised smoking cessation program: a 24-month follow-up. Am J Public Health. 1992;82:835-40. [pmid: 1585964].
268 Wewers ME, Ahijevych K, Page JA. Evaluation of a mass media community smoking cessation campaign. Addict Behav. 1991;16:289-94. [pmid: 1776544].
269 Flay BR, Gruder CL, Warnecke RB, Jason LA, Peterson P. One year follow-up of the Chicago televised smoking cessation program. Am J Public Health. 1989;79:1377-80. [pmid: 2782506].
270 Jason LA, Gruder CL, Martino S, Flay BR, Warnecke R, Thomas N. Work site group meetings and the effectiveness of a televised smoking cessation intervention. Am J Community Psychol. 1987;15:57-72. [pmid: 3604994].
271 Gruder CL, Warnecke RB, Jason LA, Flay BR, Peterson P. A televised, self-help, cigarette smoking cessation intervention. Addict Behav. 1990;15:505-16. [pmid: 2075848].
272 Gruder CL, Mermelstein RJ, Kirkendol S, et al. Effects of social support and relapse prevention training as adjuncts to a televised smoking-cessation intervention. J Consult Clin Psychol. 1993;61:113-20. [pmid: 8450096].
273 Jason L, Gruder CL, Buckenberger L, et al. A 12-month follow-up of a worksite smoking cessation intervention. Health Education Research. 1987;2:185-94.
274 Jason LA, Lesowitz T, Michaels M, et al. A worksite smoking cessation intervention involving the media and incentives. Am J Community Psychol. 1989;17:785-99. [pmid: 2636539].
275 Kviz FJ, Crittenden KS, Belzer LJ, Warnecke RB. Psychosocial factors and enrollment in a televised smoking cessation program. Health Educ Q. 1991;18:445-61. [pmid: 1757267].
276 Kviz FJ, Crittenden KS, Clark MA, Madura KJ, Warnecke RB. Buddy support among older smokers in a smoking cessation program. Journal of Aging and Health. 1994;6:229-54.
277 McFall SL, Michener A, Rubin D, et al. The effects and use of maintenance newsletters in a smoking cessation intervention. Addict Behav. 1993;18:151-8. [pmid: 8506786].
278 Smillie C, Coffin K, Porter K, Ryan B. Primary health care through a community based smoking-cessation program. J Community Health. 1988;13:156-70. [pmid: 3230154].
279 Warnecke RB, Langenberg P, Gruder CL, Flay BR, Jason LA. Factors in smoking cessation among participants in a televised intervention. Prev Med. 1989;18:833-46. [pmid: 2626416].
280 Warnecke RB, Flay BR, Kviz FJ, et al. Characteristics of participants in a televised smoking cessation intervention. Prev Med. 1991;20:389-403. [pmid: 1862060].
281 Centers for Disease Control and Prevention. Impact of promotion of the Great American Smokeout and availability of over-the-counter nicotine medications, 1996. MMWR Morbidity & Mortality Weekly Report. 1997;46(37):867-71. [pmid: 9310210].
282 Chapman S, Smith W, Mowbray G, Hugo C, Egger G. Quit and win smoking cessation contests: how should effectiveness be evaluated?. Prev Med. 1993;22:423-32. [pmid: 8327422].
283 Chapman S, Smith W. Deception in quit smoking lottery entrants. American Journal of Health Promotion. 1994;8:328-30. [pmid: 10172074].
284 Donovan RJ, Fisher DA, Armstrong BK. "Give it away for a day": an evaluation of Western Australia's first smoke free day. Community Health Studies. 1984;8:301-6. [pmid: 6518749].
285 Elder JP, McGraw SA, Rodrigues A, et al. Evaluation of two community-wide smoking cessation contests. Prev Med. 1987;16:221-34. [pmid: 3588563].
286 Elder JP, Campbell NR, Mielchen SD, Hovell MF, Litrownik AJ. Implementation and evaluation of a community-sponsored smoking cessation contest. American Journal of Health Promotion. 1991;5:200-7. [pmid: 10148669].
287 Glasgow RE, Klesges RC, Mizes JS, Pechacek TF. Quitting smoking: strategies used and variables associated with success in a stop-smoking contest. J Consult Clin Psychol. 1985;53:905-12. [pmid: 4086690].
288 Gritz ER, Carr CR, Marcus AC. Unaided smoking cessation: Great American Smokeout and New Year's Day quitters. Special Issue: Clinical research issues in psychosocial oncology. Journal of Psychosocial Oncology. 1988;6:217-34.
289 Hantula D, Stillman FA, Waranch HR. Can a mass media campaign modify tobacco smoking in a large organization? Evaluation of the Great American Smokeout in an urban hospital. Journal of Organizational Behavior Management. 1992;13:33-47.
290 King AC, Flora JA, Fortmann SP, Taylor CB. Smokers' challenge: immediate and long-term findings of a community smoking cessation contest. Am J Public Health. 1987;77:1340-1. [pmid: 3631371].
291 Korhonen T, Urjanheimo E, Mannonen P, Korhonen HJ, Uutela A, Puska P. Quit and Win campaigns as a long-term anit-smoking intervention in North Karelia and other parts of Finland. Tob Control. 1999;8:175-81. [pmid: 10478402].
292 Lando HA, Loken B, Howard-Pitney B, Pechacek T. Community impact of a localized smoking cessation contest. Am J Public Health. 1990;80:601-3. [pmid: 2109545].
293 Lando HA, Pirie PL, Dusich KH, Elsen C, Bernards J. Community incorporation of quit and win contests in Bloomington, Minnesota [news]. Am J Public Health. 1995;85:263-4. [pmid: 7856789].
294 Leinweber CE, Macdonald JM, Campbell HS. Community smoking cessation contests: an effective public health strategy. Can J Public Health. 1994;85:95-8. [pmid: 8012926].
295 Resnicow K, Vaughan R, Futterman R, et al. A self-help smoking cessation program for inner-city African Americans: results from the Harlem Health Connection Project. Health Education and Behavior. 1997;24:201-17. [pmid: 9079579].
296 Tillgren P, Haglund BJ, Ainetdin T, Holm LE. Who is a successful quitter? One-year follow-up of a National Tobacco Quit and Win Contest in Sweden. Scand J Soc Med. 1995;23:193-201. [pmid: 8602490].
297 Resnicow K, Futterman R, Weston RE, et al. Smoking Prevalence in Harlem, New York. American Journal of Health Promotion. 1996;10:343-6. [pmid: 10163304].
298 Resnicow K, Royce J, Vaughan R, Orlandi MA, Smith M. Analysis of a multicomponent smoking cessation project: what worked and why. Prev Med. 1997;26:373-81. [pmid: 9144762].
299 Tillgren P, Haglund BJ, Gilljam H, Holm LE. A tobacco quit and win model in the Stockholm cancer prevention programme. Eur J Cancer Prev. 1992;1:361-6. [pmid: 1463988].
300 US Preventive Services Task Force. Guide to Clinical Preventive Services: report of the U.S. Preventive Services Task Force. 2nd ed. Baltimore: Williams & Wilkins, 1996.
301 Chang HC, Zimmerman LH, Beck JM. Impact of chart reminders on smoking cessation practices of pulmonary physicians. Am J Respir Crit Care Med. 1995;152:984-7. [pmid: 7663814].
302 Dietrich AJ, O'Conner GT, Keller A, Carney PA, Levy D, Whaley FS. Cancer: improving early detection and prevention. A community practice randomised trial. BMJ. 1992;304:687-91. [pmid: 1571644].
303 Fiore MC, Jorenby DE, Schensky AE, Smith SS, Bauer RR, Baker TB. Smoking status as the new vital sign: effect on assessment and intervention in patients who smoke [see comments]. Mayo Clin Proc. 1995;70:209-13. [pmid: 7861807].
304 Hahn DL, Berger MG. Implementation of a systematic health maintenance protocol in a private practice [see comments]. [Review] [51 refs]. J Fam Pract. 1990;31:492-502. [pmid: 2230674].
305 Robinson MD, Laurent SL, Little JJ. Including smoking status as a new vital sign: it works. J Fam Pract. 1995;40:556-61. [pmid: 7775909].
306 Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. Can Med Assoc J. 1991;145:807-13. [pmid: 1913409].
307 Strecher VJ, O'Malley MS, Villagra VG, et al. Can residents be trained to counsel patients about quitting smoking? Results from a randomized trial [see comments]. J Gen Intern Med. 1991;6:9-17. [pmid: 1999752].
308 Spencer E, Swanson T, Hueston WJ, Edberg DL. Tools to improve documentation of smoking status. Continuous quality improvement and electronic medical records. Arch Fam Med. 1999;8:18-22. [pmid: 9932067].
309 Allen SS, Bland CJ, Dawson SJ. A mini-workshop to train medical students to use a patient-centered approach to smoking cessation. Am J Prev Med. 1990;6:28-33. [pmid: 2340189].
310 Anonymous. The impact of providing physicians with quit-smoking materials for smoking patients. CA Cancer J Clin. 1981;31:75-8. [pmid: 6781721].
311 Carney PA, Dietrich AJ, Freeman DJ, Mott LA. A standardized-patient assessment of a continuing medical education program to improve physicians' cancer-control clinical skills. Acad Med. 1995;70:52-8. [pmid: 7826445].
312 Chu F, Day R. Smoking recognition by family physicians. J Fam Pract. 1981;12:657-60. [pmid: 7205168].
313 Cockburn J, Ruth D, Silagy C, et al. Randomised trial of three approaches for marketing smoking cessation programmes to Australian general practitioners [see comments]. BMJ. 1992;304:691-4. [pmid: 1571645].
314 Duncan C, Stein MJ, Cummings SR. Staff involvement and special follow-up time increase physicians' counseling about smoking cessation: a controlled trial. Am J Public Health. 1991;81:899-901. [pmid: 2053669].
315 Dunkley J. Training midwives to help pregnant women stop smoking. Nursing Times. 1997;93:64-6. [pmid: 9070004].
316 Giovino GA, Cummings KM, Koenigsberg MR, Sciandra RC. An evaluation of a physician training program on patient smoking cessation. Prog Clin Biol Res. 1990;339:27-48. [pmid: 2392425].
317 Hall MN, Pettice YJ, Robinson MD, Alexander M. Teaching smoking cessation to family practice residents: an experiential approach. Fam Med. 1996;28:331-6. [pmid: 8735059].
318 Klein JD, Portilla M, Goldstein A, Leininger L. Training pediatric residents to prevent tobacco use. Pediatrics. 1995;96:326-30. [pmid: 7630693].
319 Leininger LS, Earp JA. The effect of training staff in office-based smoking cessation counseling. Patient Education & Counseling. 1993;20:17-25. [pmid: 8474944].
320 McIlvain HE, Susman JL, Manners MA, Davis CM, Gilbert CS. Improving smoking cessation counseling by family practice residents. J Fam Pract. 1992;34:745-9. [pmid: 1593249].
321 Montner P, Bennett G, Brown C. An evaluation of a smoking cessation training program for medical residents in an inner-city hospital. J Natl Med Assoc. 1994;86:671-5. [pmid: 7966429].
322 Ockene JK, Lindsay EA, Hymowitz N, et al. Tobacco control activities of primary-care physicians in the Community Intervention Trial for Smoking Cessation. COMMIT Research Group. Tob Control. 1997;6 Suppl 2:S49-S56. [pmid: 9583653].
323 Patterson J, Fried RA, Nagle JP. Impact of a comprehensive health promotion curriculum on physician behavior and attitudes. Am J Prev Med. 1989;5:44-9. [pmid: 2742789].
324 Quirk M, Ockene J, Kristeller J, et al. Training family practice and internal medicine residents to counsel patients who smoke: improvement and retention of counseling skills. Fam Med. 1991;23:108-11. [pmid: 2037209].
325 Roche AM, Eccleston P, Sanson-Fisher R. Teaching smoking cessation skills to senior medical students: a block-randomized controlled trial of four different approaches. Prev Med. 1996;25:251-8. [pmid: 8781002].
326 Rodney WM, Nutter D, Widoff B. Recording patients' consumption of social drugs in a family medicine residency: a longitudinal study. Fam Pract. 1985;2:86-90. [pmid: 3874104].
327 Royce JM, Gorin SS, Edelman B, Rendino-Perrone R, Orlandi MA. Student nurses and smoking cessation. Prog Clin Biol Res. 1990;339:49-71. [pmid: 2392438].
328 Russell MA, Stapleton JA, Jackson PH, Hajek P, Belcher M. District programme to reduce smoking: effect of clinic supported brief intervention by general practitioners. BMJ (Clinical Research Ed ). 1987;295:1240-4. [pmid: 3120963].
329 Secker-Walker RH, Solomon LJ, Flynn BS, Skelly JM, Mead PB. Reducing smoking during pregnancy and postpartum: Physician's advice supported by individual counseling. Prev Med. 1998;27:422-30. [pmid: 9612832].
330 Ward J, Sanson-Fisher R. Does a 3-day workshop for family medicine trainees improve preventive care? A randomized control trial. Prev Med. 1996;25:741-7. [pmid: 8936577].
331 Wood GJ, Cecchini JJ, Nathason N, Hiroshige K. Office-based training in tobacco cessation for dental professionals. J Am Dent Assoc. 1997;128:216-24. [pmid: 9037977].
332 Dietrich AJ, Barrett J, Levy D, Carney-Gersten P. Impact of an educational program on physician cancer control knowledge and activities. Am J Prev Med. 1990;6:346-52. [pmid: 2076303].
333 Ockene JK, Quirk ME, Goldberg RJ, et al. A residents' training program for the development of smoking intervention skills [see comments]. Arch Intern Med. 1988;148:1039-45. [pmid: 3365074].
334 Allen B, Pederson LL, Leonard EH. Effectiveness of physicians-in-training counseling for smoking cessation in African Americans. J Natl Med Assoc. 1998;90:597-604. [pmid: 9803724].
335 Cohen SJ, Stookey GK, Katz BP, Drook CA, Smith DM. Encouraging primary care physicians to help smokers quit. A randomized, controlled trial. Ann Intern Med. 1989;110:648-52. [pmid: 2930095].
336 Cohen SJ, Stookey GK, Katz BP, Drook CA, Christen AG. Helping smokers quit: a randomized controlled trial with private practice dentists. J Am Dent Assoc. 1989;118:41-5. [pmid: 2913103].
337 Conger B, Nelson EC, Dietrich AJ, et al. Effectiveness of physician antismoking advice. Am J Prev Med. 1987;3:223-6. [pmid: 3330661].
338 Cummings SR, Richard RJ, Duncan CL, et al. Training physicians about smoking cessation: a controlled trial in private practice. J Gen Intern Med. 1989;4:482-9. [pmid: 2685206].
339 Cummings SR, Coates TJ, Richard RJ, et al. Training physicians in counseling about smoking cessation. A randomized trial of the "Quit for Life" program. Ann Intern Med. 1989;110:640-7. [pmid: 2930094].
340 Davies BL, Matte-Lewis L, O'Connor AM, Dulberg CS, Drake ER. Evaluation of the "Time to Quit" self-help smoking cessation program. Can J Public Health. 1992;83:19-23. [pmid: 1571877].
341 Gilbert JR, Wilson DM, Singer J, et al. A family physician smoking cessation program: an evaluation of the role of follow-up visits. Am J Prev Med. 1992;8:91-5. [pmid: 1599726].
342 Goldberg DN, Hoffman AM, Farinha MF, et al. Physician delivery of smoking-cessation advice based on the stages-of-change model. Am J Prev Med. 1994;10:267-74. [pmid: 7848669].
343 Hartmann KE, Thorp JMJ, Pahel-Short L, Koch MA. A randomized controlled trial of smoking cessation intervention in pregnancy in an academic clinic. Obstet Gynecol. 1996;87:621-6. [pmid: 8602320].
344 Hovell MF, Slymen DJ, Jones JA, et al. An adolescent tobacco-use prevention trial in orthodontic offices. Am J Public Health. 1996;86:1760-6. [pmid: 9003134].
345 Kosower E, Ernst A, Taub B, Berman N, Andrews J, Seidel J. Tobacco prevention education in a pediatric residency program. Archives of Pediatrics and Adolescent Medicine. 1995;149:430-5. [pmid: 7704172].
346 Kottke TE, Brekke ML, Solberg LI, Hughes JR. A randomized trial to increase smoking intervention by physicians. Doctors Helping Smokers, Round I. JAMA. 1989;261:2101-6. [pmid: 2926945].
347 Kottke TE, Solberg LI, Brekke ML, Conn SA, Maxwell P, Brekke MJ. A controlled trial to integrate smoking cessation advice into primary care practice: Doctors Helping Smokers, Round III. J Fam Pract. 1992;34:701-8. [pmid: 1593243].
348 McPhee S, Bird J, Fordham D, Rodnick J. Promoting cancer prevention activities by primary care physicians: results of a randomized, controlled trial. JAMA. 1991;266:538-44. [pmid: 2061981].
349 Morgan GD, Noll EL, Orleans CT, Rimer BK, Amfoh K, Bonney G. Reaching midlife and older smokers: tailored interventions for routine medical care. Prev Med. 1996;25:346-54. [pmid: 8781013].
350 Narce-Valente S, Kligman EW. Increasing physician screening and counseling for passive smoking. J Fam Pract. 1992;34:722-8. [pmid: 1593246].
351 Ockene JK, Kristeller J, Pbert L, et al. The physician-delivered smoking intervention project: can short-term interventions produce long-term effects for a general outpatient population?. Health Psychol. 1994;13:278-81. [pmid: 8055863].
352 Petersen L, Handel J, Kotch J, Podedworny T, Rosen A. Smoking reduction during pregnancy by a program of self-help and clinical support. Obstet Gynecol. 1992;79:924-30. [pmid: 1579315].
353 Richmond R, Mendelsohn C, Kehoe L. Family physicians' utilization of a brief smoking cessation program following reinforcement contact after training: a randomized trial. Prev Med. 1998;27:77-83. [pmid: 9465357].
354 Rigotti NA, Arnsten JH, McKool KM, Wood-Reid KM, Pasternak RC, Singer DE. Efficacy of a smoking cessation program for hospital patients. Arch Intern Med. 1997;157:2653-60. [pmid: 9531235].
355 Solberg LI, Maxwell PL, Kottke TE, Gepner GJ, Brekke ML. A systematic primary care office-based smoking cessation program. J Fam Pract. 1990;30:647-54. [pmid: 2345333].
356 Stevens VJ, Severson H, Lichtenstein E, Little SJ, Leben J. Making the most of a teachable moment: a smokeless-tobacco cessation intervention in the dental office. Am J Public Health. 1995;85:231-5. [pmid: 7856783].
357 Wall MA, Severson HH, Andrews JA, Lichtenstein E, Zoref L. Pediatric office-based smoking intervention: impact on maternal smoking and relapse [see comments]. Pediatrics. 1995;96:622-8. [pmid: 7567321].
358 Wilson DM, Taylor DW, Gilbert JR, et al. A randomized trial of a family physician intervention for smoking cessation. JAMA. 1988;260:1570-4. [pmid: 3411737].
359 Windsor RA, Lowe JB, Perkins LL, et al. Health education for pregnant smokers: its behavioral impact and cost benefit. Am J Public Health. 1993;83:201-6. [pmid: 8427323].
360 Leshan LA, Fitzsimmons M, Marbella A, Gottlieb M. Increasing clinical prevention efforts in a family practice residency program through CQI methods. Journal on Quality Improvement. 1997;23:391-400.
361 Manfredi C, Crittenden KS, Warnecke RB, Engler J, Cho YI, Shaligram C. Evaluation of a motivational smoking cessation intervention for women in public health clinics. Prev Med. 1999;28:51-60. [pmid: 9973588].
362 Sinclair HK, Bond CM, Lennox AS, Silcock J, Windfield AJ, Donnan PT. Training pharmacists and pharmacy assistants in the stage-of-change model of smoking cessation: a randomised controlled trial in Scotland. Tob Control. 1998;7:253-61. [pmid: 9825420].
363 Hollis JF, Lichtenstein E, Vogt TM, Stevens VJ, Biglan A. Nurse-assisted counseling for smokers in primary care. Ann Intern Med. 1993;118:521-5. [pmid: 8442622].
364 Secker-Walker RH, Solomon LJ, Flynn BS, et al. Training obstetric and family practice residents to give smoking cessation advice during prenatal care. Am J Obstet Gynecol. 1992;166:1356-63. [pmid: 1595791].
365 Manfredi C, Crittenden KS, Cho YI, Engler J, Warnecke RB. The effect of a structured smoking cesation program, independent of exposure to existing interventions. Am J Public Health. 2000;90:751-6. [pmid: 10800424].
366 Manfredi C, Crittenden KS, Cho YI, Engler J, Warnecke RB. Minimal smoking cessation interventions in prenatal, family planing, and well-child public health clinics. Am J Public Health. 2000;90:423-7. [pmid: 10705864].
367 Hebert JR, Kristeller J, Ockene JK, et al. Patient characteristics and the effect of three physician-delivered smoking interventions. Prev Med. 1992;21:557-73. [pmid: 1438106].
368 Kottke TE, Solberg LI, Conn S, et al. A comparison of two methods to recruit physicians to deliver smoking cessation interventions. Arch Intern Med. 1990;150:1477-81. [pmid: 2369245].
369 Lindsay-McIntyre E, Wilson D, Best JA, et al. The impact of a continuing education package for smoking cessation on physicians' clinical behavior and patient smoking. Proceedings of the—Annual Conference on Research in Medical Education. 1987;26:14-9.
370 Little SJ, Stevens VJ, Severson HH, Lichtenstein E. Effective smokeless tobacco intervention for dental hygiene patients. [Review] [45 refs]. Journal of Dental Hygiene. 1992;66:185-90. [pmid: 1625002].
371 Ockene JK, Kristeller J, Goldberg R, et al. Increasing the efficacy of physician-delivered smoking interventions: a randomized clinical trial [see comments]. J Gen Intern Med. 1991;6:1-8. [pmid: 1999742].
372 Rosal MC, Ockene JK, Hurley TG, Kalan K, Hebert JR. Effectiveness of nicotine-containing gum in the Physician-Delivered Smoking Intervention Study. Prev Med. 1998;27:262-7. [pmid: 9579005].
373 Cohen SJ, Christen AG, Katz BP, et al. Counseling medical and dental patients about cigarette smoking: the impact of nicotine gum and chart reminders. Am J Public Health. 1987;77:313-6. [pmid: 3812837].
374 Lindsay EA, Wilson D, Best JA, Singer J, Gilbert JR, Taylor DW. A randomized trial of physician training for smoking cessation. American Journal of Health Promotion. 1989;3:11-8.
375 Windsor RA, Lowe JB, Artz L, Contreras L. Smoking cessation and pregnancy intervention trial: preliminary mid-trial results. Prog Clin Biol Res. 1990;339:107-17. [pmid: 2202988].
376 Hollis JF, Lichtenstein E, Mount K, Vogt TM, Stevens VJ. Nurse-assisted smoking counseling in medical settings: minimizing demands on physicians. Prev Med. 1991;20:497-507. [pmid: 1871078].
377 Lichtenstein E, Hollis J. Patient referral to a smoking cessation program: who follows through?. J Fam Pract. 1992;34:739-44. [pmid: 1593248].
378 Whitlock EP, Vogt TM, Hollis JF, Lichtenstein E. Does gender affect response to a brief clinic-based smoking intervention?. Am J Med. 1997;13:159-66.
379 Ewart CK, Li VC, Coates TJ. Increasing physicians' antismoking influence by applying an inexpensive feedback technique. Journal of Medical Education. 1983;58:468-73. [pmid: 6854609].
380 Frame P, Kowulich B, Llewellyn A. Improving physician compliance with a health maintenance protocol. J Fam Pract. 1984;19:341-4. [pmid: 6470636].
381 Kern D, Harris W. Use of an outpatient medical record audit to achieve educational objectives. J Gen Intern Med. 1990;5:218-24. [pmid: 2341921].
382 Shank JC, Powell T, Llewelyn J. A five-year demonstration project association with improvement in physician health maintenance behavior. Fam Med. 1989;21:273-8. [pmid: 2753254].
383 Bonevski B, Sanson-Fisher RW, Campbell E, Carruthers A, Reid AL, Ireland M. Randomized controlled trial of a computer strategy to increase general practitioner preventive care. Prev Med. 1999;29:478-86. [pmid: 10600428].
384 Cox JL, McKenna JP. Nicotine gum: does providing it free in a smoking cessation program alter success rates?. J Fam Pract. 1990;31:278-80. [pmid: 2391458].
385 Curry SJ, Grothaus LC, McAfee T, Pabiniak C. Use and cost effectiveness of smoking-cessation services under four insurance plans in a health maintenance organization. N Engl J Med. 1998;339:673-9. [pmid: 9725926].
386 Hughes JR, Wadland WC, Fenwick JW, Lewis J, Bickel WK. Effect of cost on the self-administration and efficacy of nicotine gum: a preliminary study. Prev Med. 1991;20:486-96. [pmid: 1908080].
387 Johnson RE, Hollis JF, Stevens VJ, Woodson GT. Patterns of nicotine gum use in a health maintenance organization. DICP. 1991;25:730-5. [pmid: 1949928].
388 Schauffler H. A randomized controlled trial to assess the impact of first dollar coverage of a comprehensive smoking cessation treatment benefit on smokers in IPA model HMOs. Final report to the Robert Wood Johnson Foundation. 2000.
389 Cromwell J, Bartosch WJ, Fiore MC, Hasselblad V, Baker T. Cost-effectiveness of the clinical practice recommendations in the AHCPR guideline for smoking cessation. Agency for Health Care Policy and Research. JAMA. 1997;278:1759-66. [pmid: 9388153].
390 Sofian NS, McAfee T, Wilson J, Levan S. Telephone smoking cessation intervention: the Free and Clear Program. HMO Practice. 1995;9:144-6. [pmid: 10151100].
391 Bachman DS. Smoking cessation via telephone counseling & tools for helping your patients quit smoking once and for all. J Ark Med Soc. 1997;94:147-8. [pmid: 9308313].
392 Curry SJ, McBride C, Grothaus LC, Louie D, Wagner EH. A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. J Consult Clin Psychol. 1995;63:1005-14. [pmid: 8543703].
393 Decker BD, Evans RG. Efficacy of a minimal contact version of a multimodal smoking cessation program. Addict Behav. 1989;14:487-91. [pmid: 2589126].
394 Dubren R. Self-reinforcement by recorded telephone messages to maintain nonsmoking behavior. J Consult Clin Psychol. 1977;45:358-60. [pmid: 864049].
395 Gebauer C, Kwo CY, Haynes EF, Wewers ME. A nurse-managed smoking cessation intervention during pregnancy. J Obstet Gynecol Neonatal Nurs. 1998;27:47-53. [pmid: 9475127].
396 Glasgow RE, Hollis JF, McRae SG, Lando HA, LaChance P. Providing an integrated program of low intensity tobacco cessation services in a health maintenance organization. Health Education Research. 1991;6:87-9. [pmid: 10148728].
397 Glasgow RE, Whitlock EP, Eakin EG, Lichtenstein E. A brief smoking cessation intervention for women in low-income planned parenthood clinics. Am J Public Health. 2000;90:786-9. [pmid: 10800431].
398 Johnson JL, Budz B, Mackay M, Miller C. Evaluation of a nurse-delivered smoking cessation intervention for hospitalized patients with cardiac disease. Heart & Lung. 1999;28:55-64. [pmid: 9915931].
399 Lando HA, Hellerstedt WL, Pirie PL, McGovern PG. Brief supportive telephone outreach as a recruitment and intervention strategy for smoking cessation. Am J Public Health. 1992;82:41-6. [pmid: 1536333].
400 Lando HA, Pirie PL, Roski J, McGovern PG, Schmid LA. Promoting abstinence among relapsed chronic smokers: the effect of telephone support. Am J Public Health. 1996;86:1786-90. [pmid: 9003138].
401 Lando HA, Rolnick S, Klevan D, Roski J, Cherney L, Lauger G. Telephone support as an adjunct to transdermal nicotine in smoking cessation. Am J Public Health. 1997;87:1670-4. [pmid: 9357351].
402 Lewis SF, Piasecki TM, Fiore MC, Anderson JE, Baker TB. Transdermal nicotine replacement for hospitalized patients: a randomized clinical trial. Prev Med. 1998;27:296-303. [pmid: 9579010].
403 McBride CM, Curry SJ, Lando HA, Pirie PL, Grothaus LC, Nelson JC. Prevention of relapse in women who quit smoking during pregnancy. Am J Public Health. 1999;89:706-11. [pmid: 10224982].
404 McBride CM, Scholes D, Grothaus LC, Curry SJ, Ludman E, Albright J. Evaluation of a minimal self-help smoking cessation intervention following cervical cancer screening. Prev Med. 1999;29:133-8. [pmid: 10446040].
405 Miller N, Smith P, DeBusk RF, Sobel DS, Taylor CB. Smoking cessation in hospitalized patients: results of a randomized trial. Arch Fam Med. 1997;157:409-15.
406 Orleans CT, Schoenbach VJ, Wagner EH, et al. Self-help quit smoking interventions: Effects of self-help materials, social support instructions, and telephone counseling. J Consult Clin Psychol. 1991;59:439-48. [pmid: 2071729].
407 Orleans CT, Boyd NR, Bingler R, et al. A self-help intervention for African American smokers: Tailoring cancer information service counseling for a special population. Prev Med. 1998;27 (5 Pt 2):S61-S70. [pmid: 9808825].
408 Ossip-Klein DJ, Giovino GA, Megahed N, et al. Effects of a smoker's hotline: results of a 10-county self-help trial. J Consult Clin Psychol. 1991;59:325-32. [pmid: 2030195].
409 Ossip-Klein DJ, Carosella AM, Krusch DA. Self-help interventions for older smokers [see comments]. Tob Control. 1997;6:188-93. [pmid: 9396102].
410 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, individualized, interactive, and personalized self-help programs for smoking cessation. Health Psychol. 1993;12:399-405. [pmid: 8223364].
411 Racelis MC, Lombardo K, Verdin J. Impact of telephone reinforcement of risk reduction education on patient compliance. Journal of Vascular Nursing. 1998;16:16-20. [pmid: 9764028].
412 Sexton M, Hebel JR. A clinical trial of change in maternal smoking and its effect on birth weight. JAMA. 1984;251:911-5. [pmid: 6363731].
413 Simon JA, Solkowitz SN, Carmody TP, Browner WS. Smoking cessation after surgery, a randomized trial. Arch Fam Med. 1997;157:1371-6.
414 Stevens VJ, Glasgow RE, Hollis JF, Lichtenstein E, Vogt TM. A smoking-cessation intervention for hospital patients. Med Care. 1993;31:65-72. [pmid: 8417271].
415 Thompson B, Kinne S, Lewis FM, Woolridge JA. Randomized telephone smoking-intervention trial initially directed at blue-collar workers. J Natl Cancer Inst Monogr. 1993;(14):105-12. [pmid: 8123347].
416 Weissfeld JL, Holloway JL. Treatment for cigarette smoking in a Department of Veterans Affairs outpatient clinic. Arch Intern Med. 1991;151:973-7. [pmid: 2025147].
417 Westman EC, Levin ED, Rose JE. The nicotine patch in smoking cessation. A randomized trial with telephone counseling. Arch Intern Med. 1993;153:1917-23. [pmid: 8250653].
418 Zhu SH, Stretch V, Balabanis M, Rosbrook B, Sadler G, Pierce JP. Telephone counseling for smoking cessation: Effects of single-session and multiple-session interventions. J Consult Clin Psychol. 1996;64:202-11. [pmid: 8907100].
419 Britt J, Curry SJ, McBride C, Grothaus L, Louie D. Implementation and acceptance of outreach telephone counseling for smoking cessation with nonvolunteer smokers. Health Educ Q. 1994;21:55-68. [pmid: 8188493].
420 Glasgow RE, Lando H, Hollis J, McRae SG, La Chance PA. A stop-smoking telephone help line that nobody called. Am J Public Health. 1993;83:252-3. [pmid: 8427333].
421 Hebel JR, Nowicki P, Sexton M. The effect of antismoking intervention during pregnancy: an assessment of interactions with maternal characteristics. Am J Epidemiol. 1985;122:135-48. [pmid: 4014191].
422 Kinne S, Thompson B, Wooldridge JA. Response to a telephone smoking information line. American Journal of Health Promotion. 1991;5:410-3. [pmid: 10146839].
423 Meenan RT, Stevens VJ, Hornbrook MC, et al. Cost-effectiveness of a hospital-based smoking cessation intervention. Med Care. 1998;36:670-8. [pmid: 9596058].
424 Taylor CB, Miller N, Herman S, et al. A nurse-managed smoking cessation program for hospitalized smokers. Am J Public Health. 1996;86:1557-60. [pmid: 8916520].
425 Vogt TM, Lichtenstein E, Ary D, et al. Integrating tobacco intervention into a health maintenance organization: The TRACC program. Special Issue: Smoking. Health Education Research. 1989;4:125-35.
426 Croghan IT, Offord KP, Evans RW, et al. Cost-effectiveness of treating nicotine dependence: the Mayo Clinic experience. Mayo Clin Proc. 1997;72:917-24. [pmid: 9379693].
427 Ershoff DH, Aaronson NK, Danaher BG, Wasserman FW. Behavioral, health, and cost outcomes of an HMO-based prenatal health education program. Public Health Rep. 1983;98:536-47. [pmid: 6419268].
428 Krumholz HM, Cohen BJ, Tsevat J, Pasternak RC, Weinstein MC. Cost-effectiveness of a smoking cessation program after myocardial infarction [see comments]. J Am Coll Cardiol. 1993;22:1697-702. [pmid: 8227841].
429 Marks JS, Koplan JP, Hogue CJ, Dalmat ME. A cost-benefit/cost-effectiveness analysis of smoking cessation for pregnant women. Am J Prev Med. 1990;6:282-9. [pmid: 2125228].

## Appendix A

### Methods

In the Guide to Community Preventive Services: Systematic Reviews and Evidence-Based Recommendations (the Community Guide), evidence is summarized regarding (1) the effectiveness of interventions; (2) the applicability of evidence data (i.e., the extent to which available effectiveness data might apply to other populations and settings); (3) other positive or negative effects of the intervention, including positive or negative health and nonhealth outcomes; (4) economic impact; and (5) barriers to implementation of interventions. The process that was used to systematically review evidence and then translate that evidence into the conclusions made in this paper involved:

- forming an evidence review and chapter development team;
- developing a conceptual approach to organizing, grouping, and selecting interventions;
- selecting interventions to evaluate;
- searching for and retrieving evidence;
- assessing the quality of and abstracting information from each study;
- assessing the quality of and drawing conclusions about the body of evidence of effectiveness;
- translating the evidence of effectiveness into recommendations;
- considering data regarding applicability, other effects, economic impact, and barriers to implementation; and
- identifying and summarizing research gaps.

This appendix summarizes how these methods were used in developing the reviews of selected interventions to reduce tobacco use and exposure to environmental tobacco smoke (ETS). The Community Guide's methods for systematic reviews and linking evidence to recommendations have been published elsewhere. ^1^

The reviews of strategies to reduce tobacco use and ETS exposure were produced by a multidisciplinary team of national and regional experts representing a variety of perspectives on tobacco prevention and control (see authorship and acknowledgement lists). The chapter development team drafted the conceptual approach to the chapter (see text).

### Selecting Interventions for Evaluation

The intervention reviews included in this chapter were selected for evaluation by the chapter development team. An initial, comprehensive list of interventions in the areas included in the conceptual approach (i.e., strategies to reduce ETS exposures, strategies to reduce tobacco use initiation, and strategies to increase cessation) was generated and then reviewed. By consensus, the members of the consultation team then established a priority list of interventions to include in the chapter. Instructions to the consultants were to consider interventions that are widely practiced (whether considered effective or not) and interventions they considered important (even if not widely recognized, evaluated, or implemented).

The priority list that resulted contained 10 intervention categories. Subsequent work resulted in an expansion of some categories to include more than one distinct intervention (e.g., we eventually identified several subtypes of mass media education). Some interventions could be applied to more than one goal, and were eventually evaluated for all applicable goals (e.g., increasing the unit price of tobacco products was evaluated both for reducing initiation and for increasing cessatio The initial priority strategies and the expanded list of interventions are presented in Table A-1.

Table A-1. Priority interventions selected for review

Priority Strategy Selected For Review | Interventions
Increasing the unit price for tobacco products | Increasing the unit price- Reducing Initiation Increasing the unit price- Increasing Cessation
Health care system-level interventions | Provider Reminder + Eduation ± Patient education Provider Reminder Provider Education Provider Feedback Patient telephone cessation support (multicomponent) Reducing patient out-of-pocket costs
Mass media education | Mass media campaigns-Reducing Initiation Mass media campaigns-Increasing Cessation Mass media cessation series Cessation contests
Tobacco industry restrictions | Evaluations in progress*
Product use restrictions | Smoking Bans and Restrictions
Youth access restrictions | Evaluation in progress*
School-based education | Evaluations in progress*
Site-specific interventions | Smoking Bans and Restrictions are applicable Other strategies were not evaluated in this chapter**
Community education* | Education to reduce ETS exposures in the home Other strategies were not evaluated in this chapter**
Personal / home education | Not evaluated in this chapter**

* Evaluations of these interventions will be published separately, but included in the full chapter

** See the discussion

#### Interventions Not Reviewed

Time and resource constraints precluded the review of all of the proposed interventions, including some interventions identified within priority strategies:

- Patient cessation support conducted by mail (including computer-generated messages)
- Worksite tobacco cessation interventions (such as group cessation meetings)
- Community-wide risk factor screening and counseling
- Community-wide distribution of self-help cessation materials

Some of these interventions were components of multicomponent strategies that were evaluated for this chapter.

### Search for Evidence

Electronic searches for literature were conducted in Medline, EconLit, and the database of the Office on Smoking and Health (OSH). The OSH database, a focused database of tobacco prevention and control articles, was so complete that we did not conduct searches of additional electronic databases. We also reviewed the references listed in all retrieved articles, and consulted with experts on the chapter development team. With very few exceptions (e.g., one final report to the Robert Wood Johnson Foundation), included studies were published in journals. To be included in the review, a study had to:

- have a publication date of 1980-May 2000;
- address at least one area in our conceptual framework (ETS, initiation, cessation);
- be a primary study rather than, for example, a guideline or review;
- take place in an industrialized country or countries;
- be written in English;
- meet the evidence review and Community Guide chapter development team's definition of the interventions;
- provide information on one or more outcomes related to the analytic frameworks; and
- compare a group of persons who had been exposed to the intervention with a group of persons who had not been exposed or who had been less exposed. (The comparisons could be concurrent or in the same group over a period of time.)

Our initial database searches were conducted in January 1998. A second database search was conducted in August 1999. Any study added after August 1999 was referred by members of the chapter development team or identified in the reference lists of retrieved articles.

### Abstraction and Evaluation of Studies

Each study that met the inclusion criteria was read by two reviewers, who used a standardized abstraction form to record information from the study. Any disagreements between the reviewers were reconciled by consensus among the development team members. In addition, to ensure a consistent application of assessments of study design suitability and limitations in execution quality within the body of evidence for each intervention, every evaluated study was presented and discussed in meetings of the chapter development team.

### Assessing the Suitability of Study Design

Design suitability was assessed for every identified study (Table A-2). Our study design classifications, chosen to assure consistency in the review process, sometimes differ from the classification or nomenclature used in the original studies. Non-comparative studies were excluded from further evaluation. With two exceptions, studies with least suitable designs were also excluded from further evaluations. These two exceptions occurred (1) in our assessment of smoking bans and restrictions, where before-after studies using environmental measurements of environmental tobacco smoke (ETS) were included in the body of evidence , and (2) in our assessment of the effectiveness of increasing the unit price for tobacco products, where national or regional cross-sectional and before-after studies comparing tobacco use prevalence and price by jurisdiction were included in the body of evidence.

Table A-2. Suitability of study design for assessing effectiveness in the Guide to Community Preventive Services

Suitability | Attributes
Greatest | Concurrent comparison groups and prospective measurement of exposure and outcome
Moderate | All retrospective designs or multiple pre or post measurements but no concurrent comparison group
Least | Single pre and post measurements and no concurrent comparison group or exposure and outcome measured in a single group at the same point in time

### Assessing the Quality and Summarizing the Body of Evidence of Effectiveness

Quality of study execution was systematically assessed following the published Community Guide methods and abstraction form. ^1^ ^2^ The abstraction form organizes potential limitations in execution into the following eight categories:

- definition and selection of study and comparison population(s);
- definition and measurement of exposure and intervention;
- assessment of outcomes;
- follow-up and completion rates;
- bias;
- data analysis;
- confounding; and
- miscellaneous criteria (e.g., lack of statistical power).

Execution of each study was characterized as good, fair, or limited based on the total number of categories with limitations. Good studies had none or one assessed limitation; fair studies, two to four; and limited studies, five or more. Studies with limited execution were excluded from analysis.

We abstracted information from the studies regarding the outcomes of interest specific to the intervention under evaluation. Within each strategy, however, the outcomes of interest were similar in most cases (Table A-3).

Table A-3. Intervention strategies and outcomes of interest

Strategy | Outcomes of Interest
Reduce Exposure to ETS | Self-reported exposure to ETS Environmental measurements of ETS components Self-reported tobacco use behaviors Other outcomes (e.g. knowledge or attitudes) if available and relevant
Reduce Tobacco Use Initiation | Self-reported tobacco use behaviors (e.g. use, quantity consumed) Other outcomes (e.g. knowledge or attitudes) if available and relevant
Increase Tobacco Use Cessation | Self-reported tobacco use behaviors (i.e., cessation, use) Population measurements of tobacco product consumption (e.g., state tax paid sales for cigarettes usually calculated as cigarette packs per capita) Other outcomes (e.g., knowledge or attitudes) if available and relevant
Health care system cessation interventions | Measurements of provider identification of patient smoking status (chart documented, patient self-reported receipt) Measurements of provider delivery of advice to quit to tobacco using patients (chart documented, patient self-reported receipt) Measurements of patient use of cessation therapies (such as nicotine replacement)

Unless otherwise noted, we represented results of each study as point estimates for the change in the tobacco use behavior (or provider behavior) attributable to the interventions. We then calculated percentage point changes (absolute percentage change) and baselines using the following formulas:

- For studies with before/after measurements and concurrent comparison groups:

(Ipost - I pre) - (Cpost - Cpre); baseline = I pre, where: Ipost = last reported tobacco behavior or status in the intervention group after the intervention; Ipre = reported tobacco behavior or status in the intervention group immediately before the intervention; Cpost = last reported tobacco behavior or status in the comparison group after the intervention; Cpre = reported tobacco behavior or status in the comparison group immediately before the intervention.

- For studies with post measurements only and concurrent comparison groups (common in cessation studies performed on recruited tobacco users):

Ipost - Cpost; baseline = Cpost

- For studies with before/after measurements but no concurrent comparison:

Ipost - Ipre; baseline = Ipre

When effect measures reported by the authors could not be converted into percentage point changes (for example, adjusted odds ratios for tobacco use cessation), the reported findings were described in the text. We represented data on the effect of smoking bans and restrictions on ETS exposure as relative percent changes (Ipost-Ipre/ Ipre *100). For the interventions that were multicomponent mass media campaigns, a subset of studies reported changes in terms of cigarette packs per capita per month or per year. We converted those differences into relative percent changes (Ipost - I pre) - (Cpost - Cpre)/ Ipre *100 to facilitate comparisons. As noted in the main text, effects of interventions to increase the unit price of tobacco products were expressed as price elasticity of demand measures.

We often had to select among several possible effect measures for inclusion in our summary measures of effectiveness. When available, we used measures adjusted for potential confounders in multivariate analysis in preference to crude effect measures. In studies of tobacco use cessation, where possible, we selected effect measures of verified rather than self-reported cessation, and continuous cessation (duration usually of 3 or more months) over cessation of less than 3 months' duration. No studies were excluded from evaluation strictly on the basis of an insufficient follow-up period. In one study, cessation duration of 1 week was recorded instead as a measure of cessation attempts.

To summarize the findings regarding the effectiveness of an intervention across the studies in a body of evidence, we displayed results of individual studies in tables and figures and reported median and range of effect measures. We summarized the strength of the body of evidence based on numbers of available studies, strength of their design and execution, and size and consistency of reported effects as described in detail elsewhere. ^1^

Several assumptions were made in the assessment of the evidence of effectiveness.

- Changes in tobacco use prevalence among populations of adolescents represent both changes in tobacco use initiation and any changes in adolescent cessation. In our review, changes in tobacco use prevalence in adolescents were attributed to changes in initiation.
- Changes in population consumption of tobacco products (as measured in tax-paid sales of cigarettes) include changes in tobacco use cessation. Population changes represent the combined impact of changes in cessation, changes in initiation, and changes in consumption by continuing tobacco users. In our review, changes in population consumption were attributed to changes in cessation. Because the impact of new users on population tobacco consumption is significantly smaller, we did not consider changes in population consumption of tobacco products as evidence of effectiveness in reducing tobacco use initiation.

### Other Effects

The Community Guide reviews of interventions to reduce tobacco use and ETS exposure routinely sought information on other effects (i.e., positive and negative health or nonhealth "side effects"). We sought evidence of potential harms of these population-based interventions if they were mentioned in the effectiveness literature or thought to be of importance by the chapter development team. In almost all cases, additional outcomes were not specifically addressed in the papers that we reviewed.

One exception deserves mention here. We evaluated the evidence of effectiveness of smoking bans and restrictions on tobacco use behaviors, such as daily consumption, cessation attempts, and successful cessation. Although several studies demonstrated an effect of smoking bans on increasing tobacco use cessation, other studies did not observe an effect. In addition, recent studies measuring an effect in analyses of cross-sectional survey data did not meet our study design criteria for evaluation of effectiveness. For now, the potential effects on consumption and cessation are presented as an additional positive benefit of smoking bans and restrictions. Additional evidence of effectiveness from longitudinal studies could eventually result in a determination that smoking bans increase cessation in addition to reducing exposure to ETS.

### Economic Evaluations

Methods for the economic evaluations in the Community Guide have been previously published. ^3^ Reviews of economic evaluation studies were performed if the intervention was found to be effective. To be included in the reviews, a study had to: · evaluate interventions found to be effective in the systematic reviews; · use cost, cost-effectiveness, cost-benefit, or cost-utility analysis; · provide sufficient detail to enable use and adjustment of results; · itemize costs or refer to a source of cost data; · be a primary study rather than a guideline or review; · be conducted in one or more Established Market Economies;* · have a publication date of 1976 to 1999; · be written in English.

Of 50 studies screened, 11 were included in the body of evidence. Of the 39 studies excluded, 13 looked at clinical interventions, 8 looked at interventions with insufficient evidence of effectiveness, 6 looked at other community interventions not covered within the scope of this review, and 12 failed other inclusion criteria. The 11 included studies did not conduct true cost-effectiveness analyses, because they included only program costs but not costs of illness averted (and thus overstated the net costs of the intervention). Because of this limitation, and regardless of the titles given by the authors, these studies were reclassified as cost analysis and therefore a cost per unit outcome ratio was calculated. A standardized abstraction form (available at www.thecommunityguide.org, on the tab for The Guide, select Methods, then select Economic Abstraction form) was used for abstracting and adjusting data to meet the reference case suggested by the Panel on Cost-effectiveness in Health and Medicine. ^4^ Costs were adjusted to 1997 US$. An example of the summary table of results is available at the website: www.thecommunityguide.org.

### Summarizing Barriers to Implementation of Interventions

Information regarding barriers to implementation of the interventions was abstracted from reviewed studies, and/or evaluated on the suggestion of the chapter development team. In some cases, additional information was obtained. For several reviews we included references to more detailed descriptions. Information on barriers did not affect Task Force recommendations.

### Summarizing Research Gaps

Systematic reviews in the Community Guide identify existing information on which to base public health conclusions. An important additional benefit of these reviews is identification of areas where information is lacking or of poor quality. To develop these sections, we used the following process:

- We identified remaining research questions for each intervention evaluated.
- In cases of interventions for which evidence of effectiveness was sufficient or strong, we summarized remaining questions regarding effectiveness, applicability, other effects, economic consequences, and barriers.
- In cases of interventions for which evidence of effectiveness was insufficient, we summarized remaining questions regarding effectiveness and other effects. We summarized applicability issues only if they affected the assessment of effectiveness. We decided that it would be premature to identify research gaps in barriers or economic evaluations before effectiveness was demonstrated.
- For each category of evidence, we identified issues that had emerged from the review, based on the informed judgment of the intervention review team. Several factors influenced that judgment. In general:
  - If no information or inadequate information existed to draw a conclusion regarding effectiveness, applicability, other effects, or economic evaluations, we listed these as evidence gaps.
  - When a conclusion was drawn regarding evidence, we applied team judgment to decide if additional issues remained.
  In terms of effectiveness:
  - If effectiveness was demonstrated using some but not all outcomes, we did not necessarily list all other possible outcomes as evidence gaps.
  In terms of applicability:
  - If the available evidence was thought to generalize, we did not necessarily identify as evidence gaps all subpopulations or settings where studies had not been done.
  And in terms of methods:
  - Within each body of evidence, the intervention review team considered whether overriding methodologic issues existed.

Footnote * Established Market Economies as defined by the World Bank include: Andorra, Australia, Austria, Belgium, Bermuda, Canada, Channel Islands, Denmark, Faeroe Islands, Finland, France, Former Federal Republic of Germany, Germany, Gibraltar, Greece, Greenland, Holy See, Iceland, Ireland, Isle of Man, Italy, Japan, Liechtenstein, Luxembourg, Monaco, Netherlands, New Zealand, Norway, Portugal, San Marino, Spain, St. Pierre and Miquelon, Sweden, Switzerland, the United Kingdom, and the United States.

### References

1 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services-Methods. Am J Prev Med. 2000;18 (Suppl 1S):35-43. [pmid: 10806978].
2 Zaza S, Wright-de Aguero LK, Briss PA, et al. Data collection instrument and procedures for systematic reviews in the Guide to Community Preventive Services. Am J Prev Med. 2000;18 (Suppl 1S):44-74. [pmid: 10806979].
3 Carande-Kulis VG, Maciosek MV, Briss PA, et al. Methods for systematic reviews of economic evaluations for the Guide to Community Preventive Services. Am J Prev Med. 2000;18 (Suppl 1S):75-91. [pmid: 10806980].
4 Gold MR, Siegel JE, Russell LB, Weinstein MC. Cost-effectiveness in health and medicine. New York: Oxford University Press, 1996.