# Tobacco Use Prevention and Control

Reviews of Evidence Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke

Evidence Reviews and Recommendations on Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke: A Summary of Selected Guidelines

Recommendations Regarding Interventions to Reduce Tobacco Use and Exposure to Environmental Tobacco Smoke