# The Guide To Community Preventive Services: Oral Health

Over 108 million Americans lack dental insurance, over 2.5 times the number who lack medical insurance.^ 1 ^ Community preventive services provide an essential complement to individual and professional one-on-one services aimed at preventing dental caries, oral and pharyngeal cancers, and craniofacial injuries, the three oral health conditions selected for review by the Task Force on Community Preventive Services (the Task Force). These conditions are painful, disfiguring, affect daily functioning, and can lead to loss of life. As noted by the overarching message of Oral Health in America: A Report of the Surgeon General, "oral health is essential to the general health and well-being of all Americans and can be achieved."^ 1 ^ This critical review of the evidence base is timely and thorough, and provides the nation with the capacity to further promote overall health and well-being through community-based and community-wide oral health programs.

The diseases and conditions selected by the Task Force represent those for which there is a personal and societal burden in our nation and for which preventive measures exist. In addition, these diseases and conditions reflect America's health disparities among population groups that differ due to race or ethnicity or income levels. Dental caries, an infectious disease that can be prevented by appropriate use of fluorides and pit and fissure sealants, remains the most common of chronic childhood diseases, five times more common than asthma. Individuals living in poverty are three times more likely to have untreated disease than those who are not poor. About one person dies every hour due to oral and pharyngeal cancer, a disease whose incidence is almost 40% higher in black males than in white males. Tobacco and alcohol use are estimated to account for 75% to 80% of all oral and pharyngeal cancers.^ 2 ^ Injuries of the face, mouth, and head are common. It has been estimated that one third of all dental injuries are sports-related.^ 3 ^ Helmets, face protection, and mouth guards can protect individuals from predictable events that occur during sporting events.

The Healthy People 2010 ^ 4 ^ oral health objectives focus on preventing these diseases through appropriate use of preventive measures and timely and effective examinations and screening procedures. These objectives address the need to decrease the proportion of people who have decayed, missing, or filled teeth due to dental caries; and to increase the proportion of children who have received dental sealants on their molar teeth and the proportion of the U.S. population served by community water systems with optimally fluoridated water. For oral and pharyngeal cancers, the objectives focus on thorough clinical examinations and early detection, as well as on counseling for the prevention and cessation of tobacco use. For sports-related injuries, the objectives emphasize the need to increase the proportion of schools that require protective gear for sponsored physical activities. Effective community programs could make an impact on populations at risk for developing any or all of these conditions and are essential for accomplishing the oral health objectives in Healthy People 2010.^ 4 ^

The availability of studies that met the criteria developed by the Task Force shaped the recommendations. Community water fluoridation and school-based or school-linked pit and fissure sealant programs are highly recommended for caries prevention. Insufficient evidence was found for statewide or community-wide sealant promotion programs; population-based interventions for early detection of pre-cancers and cancers; and population-based interventions to encourage use of helmets, facemasks, and mouthguards in contact sports. The authors are careful to say, however, that "insufficient evidence should not be confused with evidence of ineffectiveness."^ 5 ^ As a result, the Task Force decided not to make a recommendation for or against these latter three programs and recommended that communities use other criteria to determine their usefulness. Of particular note is the similarity of the Task Force recommendations with those of other reviews of the literature, despite use of varying review methods. ^ 5 ^

The development of a methodology for the review of community preventive services is an accomplishment in and of itself and I thank the Task Force and the Centers for Disease Control and Prevention (CDC) staff for their vision and perseverance in publishing their approach.^ 6 ^ Having a well-documented review facilitates discussion and action. We have benefited from reviews of tobacco use prevention and control, and of injury reduction to motor-vehicle occupants, services that can have a positive effect on oral and craniofacial health. I also commend the Task Force members, CDC-based staff, and the authors and team members for their thorough reviews of the science base for oral, dental, and craniofacial health community preventive services, which provides a guide to program directors and funders, policymakers, and researchers, among others.

Taking action is critical. These findings should increase our resolve to promote community water fluoridation and school-based or school-linked pit and fissure delivery programs. On-going community preventive programs must be assessed and new programs must be carefully planned and implemented. Most importantly, these programs must be evaluated, and peer-reviewed publication of short-term and long-term outcomes is essential. The CDC provides ongoing support for state and local oral health program infrastructure that in turn should facilitate the development and monitoring of these preventive efforts. At the same time, we must pursue the many research questions that are posed. Five state planning research grants for the early detection and prevention of oral cancer recently funded by the National Institutes of Health should provide new data for review.

A key point made by the Task Force is the need to reorient and redesign future research. The literature has documented studies designed to be disease-oriented and singly focused, while actions at the community level are a complex of health, social service, education, legal, regulatory, and other activities. Rarely is one service provided in isolation of others. This is well known to program directors and agencies such as the Health Resources and Services Administration, Agency for Healthcare Research and Quality, and the Indian Health Service. The Task Force appropriately calls for an ecologic framework for future investigations to allow evaluation of a variety of program settings, mixtures of interventions, range of targets of change, and range of desirable health outcomes.^ 5 ^

I urge all of us to use this report to achieve the nation's oral health promotion and disease prevention objectives. This Task Force report challenges us to use the science base and further build it so that our future efforts will be more effective and more efficient.

## References

1 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. U.S. Department of Health and Human Services, Rockville, MD (2000).
2 W.J. Blot, J.K. McLaughlin, D.M. Winn et al. Smoking and drinking in relation to oral and pharyngeal cancer. J Natl Cancer Inst. 1988;48:3282-3287.
3 R.D. Nowjack-Raymer and H.C. Gift. Use of mouthguards and headgear in organized sports by school-aged children. Public Health Rep. 1996;111:82-86. [pmid: 8610199].
4 U.S. Department of Health and Human Services. Healthy People 2010 (conference edition, in 2 vols). U.S. Department of Health and Human Services, Washington, DC (2000).
5 Task Force on Community Preventive Services. The guide to community preventive services: oral health. Am J Prev Med. 2002;23 suppl 1.
6 Task Force on Community Preventive Services. Introducing the Guide to Community Preventive Services: methods, first recommendations, and expert commentary. Am J Prev Med. 2000;18 suppl 1:1-142.