# Oral Health

The Guide To Community Preventive Services: Oral Health

Wishes for the Future

Partnering to Unlock the Mysteries of Oral Diseases and Injuries

Issues and Opportunities

The Robert Wood Johnson Foundation's Response to Improving the Nation's Oral Health

Recommendations on Selected Interventions to Prevent Dental Caries, Oral and Pharyngeal Cancers, and Sports-Related Craniofacial Injuries

Reviews of Evidence on Interventions to Prevent Dental Caries, Oral and Pharyngeal Cancers, and Sports-related Craniofacial Injuries

A Comparison of Selected Evidence Reviews and Recommendations on Interventions to Prevent Dental Caries, Oral and Pharyngeal Cancers, and Sports-related Craniofacial Injuries

Reviews and Recommendations to Prevent Dental Caries, Oral and Pharyngeal Cancers, and Sports-Related Craniofacial Injuries