# Reviews of evidence regarding interventions to increase use of child safety seats

## Overview

### Background

In 1998, nearly 600 child occupants of motor vehicles aged younger than 4 years died in motor vehicle crashes. Yet approximately 29% of children aged 4 years and younger do not ride in appropriate child safety seat restraints, which, when correctly installed and used, reduce the need for hospitalization in this age group by 69% and the risk of death by approximately 70% for infants and by 47% to 54% for toddlers (aged 1 to 4 years).

### Methods

The systematic review development team reviewed the scientific evidence of effectiveness for five interventions to increase child safety seat use. For each intervention, changes in the use of child safety seats or injury rates were the outcome measures evaluated to determine the success of the intervention. Database searching was concluded in March 1998. More than 3500 citations were screened; of these citations, 72 met the inclusion criteria for the reviews.

### Results

The systematic review process identified strong evidence of effectiveness for child safety seat laws and distribution plus education programs. In addition, community-wide information plus enhanced enforcement campaigns and incentive plus education programs had sufficient evidence of effectiveness. Insufficient evidence was identified for education-only programs aimed at parents, young children, healthcare professionals, or law enforcement personnel.

### Conclusions

Evidence is available about the effectiveness of four of the five interventions we reviewed. This scientific evidence, along with the accompanying recommendations of the Task Force elsewhere in this supplement, can be a powerful tool for securing the resources and commitment required to implement these strategies.

### Medical Subject Headings (MeSH)

accidents, traffic; motor vehicles; wounds and injuries; infant equipment; protective devices; community health services; decision making; evidence-based medicine; economics; preventive health services; public health practice

## Introduction

Motor vehicle crash-related injuries kill more children than any other single cause in the United States.1 In 1998, a total of 1765 child occupants aged 14 years and younger died in motor vehicle crashes; of those, 33% were children younger than 4 years.1 In 1999, an estimated 272,000 motor vehicle occupants aged 14 and younger were injured in crashes.2

For children aged birth to 4 years, child safety seats can be extremely effective. When correctly installed and used, child safety seats reduce the need for hospitalization in this age group by 69%3 and the risk of death by approximately 70% for infants and by 47% to 54% for toddlers (aged 1 to 4 years).4 If all child passengers aged 4 years and younger were restrained, each year an additional 162 lives could be saved and 20,000 injuries could be prevented.5,6

Approximately 29% of children aged 4 years and younger do not ride in appropriate restraints, placing them at twice the risk of fatal and nonfatal injuries of those riding restrained.2,7,8 In addition, approximately 85% of children riding in child safety seats are improperly restrained.9 Seating position imposes an additional risk factor: In passenger vehicles, children aged 12 years and younger are 36% less likely to die in a crash if seated in the back seat.10

Some groups of children are more at risk than others. Child safety seat use is lower among rural populations and low-income families.8,11-13 Lack of access to affordable child safety seats might contribute to lower usage rates among low-income families. However, when they do own a safety seat, 95% of low-income families use it,5,14-16 suggesting that strategies to increase the availability of free or low-cost child safety seats might be effective.

Given the high burden of fatal and nonfatal injury imposed on children by motor vehicle crashes, the effectiveness of child safety seats in reducing those injuries, and the continued low rate of correct use of child safety seats, we sought to identify which population-based interventions among those currently in use or contemplated by the public health community are most effective. As part of the Guide to Community Preventive Services (the Community Guide), we conducted systematic literature reviews to determine the effectiveness of population-based interventions to improve the use of child safety seats among children aged birth to 4 years.17-19

## Methods

The general methods for conducting systematic reviews for the Community Guide have been described in detail elsewhere.17,20,21 The specific methods for conducting reviews of interventions to reduce motor vehicle occupant injuries are also described in detail elsewhere in this issue.18 This section briefly describes the specific methods to define the conceptual approach, search strategy, intervention selection, and outcome determination for interventions to improve the use of child safety seats.

The general conceptual model used to evaluate the effectiveness of interventions to improve the use of child safety seats is shown in Figure 1. Interventions are designed to increase the possession and correct use of child safety seats. In turn, increased use of child safety seats reduces fatal and nonfatal injuries.

Figure 1. Conceptual approach: interventions to improve child safety seat use.

The systematic review development team (see author list and Consultation Team, in Acknowledgments) reviewed the scientific evidence of effectiveness for five interventions: child safety seat laws, community-wide information and enhanced enforcement campaigns, distribution and education programs, incentive and education programs, and education-only programs. For each of these interventions, changes in the use of child safety seats or injury rates were the outcome measures evaluated to determine the success of the intervention. Observed use of child safety seats was the preferred measure and was used when available. Some studies only provided parent-reported use, however. The measure used is specified in the evidence tables, available at the website (www.thecommunityguide.org).

Inclusion criteria for searching the literature are described in the accompanying methods article.18 These were the first interventions reviewed by the systematic review team, and database searching was concluded in March 1998. More than 3500 citations were screened; approximately 600 studies were retrieved for detailed screening. Of these studies, 72 met the inclusion criteria for the reviews.

## Results. Part I. Intervention Effectiveness and Economic Efficiency

### Child safety seat laws

Child safety seat laws require children traveling in motor vehicles to be restrained in federally approved safety seats appropriate for the child's age and size. Legislation also specifies the children to whom the law applies by age, height, weight, or a combination of these factors.

Although all states currently have child safety seat laws, a better understanding of the evidence about the effectiveness of these laws will help policymakers in their efforts to strengthen these regulations. In addition, differences in effectiveness based on the variability in state laws might bolster efforts to maintain or strengthen some state laws and to reduce gaps in coverage and protection for some children.

#### Reviews of evidence

##### Effectiveness

Our search identified 25 reports on the effectiveness of child safety seat laws.22-46 Descriptive information about the quality, study design, and outcome measures from these reports is provided in Table 1. Details of the nine independent, qualifying studies27-29,34,37,40-43 are available at the website (www.thecommunityguide.org).

Table 1. Child safety seat laws: descriptive information about included papers

| Number of studies
| Number of studies
Papers meeting inclusion criteria | 2522-46
Papers excluded, limited execution quality | 1422-26,33,34,37,40-43,45
Qualifying papers | 1127-29,33,34,37,40-43,45
Papers reporting on an already-included study | 233,45
Actual number of qualifying papers | 927-29,34,37,40-43
Study designs
Time series with concurrent comparison group | 528,29,34,41,42
Time series, no concurrent comparison group | 237,40
Before-after with concurrent comparison group | 143
Nonparametric modeling | 127
Outcomes reported
Fatal injuries | 327,41,42
Fatal and nonfatal injuries (or nonfatal injuries only) | 528,29,34,37,41
Child safety seat use | 340,41,43

The nine studies represent evaluations of child safety seat laws in the 50 states (the District of Columbia and Puerto Rico were not studied) that went into effect between 1978 (Tennessee) and 1986 (Alaska). The main characteristics of the laws are:

- Primary enforcement. All laws allow for primary enforcement, that is, a driver can be stopped for the sole purpose of being cited and fined for failure to comply with the child safety seat law.
- Age requirements. The laws apply to children of various ages (e.g., some apply to children up to the age of 1 year, whereas others apply to children up to the age of 5 years).
- Seating position. One study specified that the law applied only to children in the front seat; the remainder of the studies did not specify seating requirements.
- Penalties. The various laws allowed for penalties, ranging from an oral warning to a $25 fine.

None of the studies described activities related to the law such as child safety seat loan programs for low-income families, levels of enforcement, or publicity about the law. Summary effects of the systematic review for each of the outcomes of interest, measured from 1 to 12 years after enactment, are presented in Table 2.

Table 2. Effectiveness of child safety seat laws on various outcomes: summary effects from the body of evidence

Outcome | Number of outcome measures | Median change | Range
Outcome | Number of outcome measures | Median change | Range
Fatal injuries | 327,41,42 | 35% decrease | 25.0%-57.3% decrease
Fatal and nonfatal injuries combined | 528,29,34,37,41 | 17.3% decrease | 10.5%-35.9% decrease
Child safety set use | 340,41,43 | 13.0% increase | 5.0%-35.0% increase

Among the studies that evaluated the laws' effects on injury rates, no differences were observed in the effect size on the basis of the age of children who were required to be in safety seats. Too few studies reported enough information about other requirements of the laws (e.g., seating position, penalties, enforcement provisions) to determine whether decreases in injury rates varied because of these factors. Moreover, there were too few studies from each state to allow us to determine whether specific state laws affected injury rates differently.

##### Applicability

The same body of evidence was used to evaluate the applicability of these laws in different settings and populations. In these studies, all 50 states were represented, and most studies analyzed data from statewide crash reporting files. Therefore, the evidence of effectiveness should be applicable to most child passengers in the United States. However, none of the studies adequately described the study population in terms of age, gender, race, socioeconomic status, region of the state, or other parameters. In addition, none of the studies described the crash reporting systems in adequate detail to determine the extent to which these systems are valid and representative of crashes in their respective state populations. Therefore, differences in effectiveness for various subgroups of the population could not be determined.

##### Other positive or negative effects

No harms or other beneficial effects of child safety seat laws were identified from the literature.

##### Economic

No studies were found that met the requirements for inclusion in a Community Guide review.18

##### Barriers to intervention implementation

Child safety seat laws have been enacted in all 50 states and the District of Columbia. Experts in child passenger safety may encounter political barriers to strengthening the requirements of laws or to implementing or enhancing enforcement of existing laws, especially in the absence of data on how variations in existing laws are related to outcomes.

##### Conclusion

There is strong evidence of the effectiveness of child safety seat laws to reduce fatal and nonfatal injuries and to increase child safety seat use, according to the rules of evidence used for the Community Guide.

### Community-wide information and enhanced enforcement campaigns

Community-wide information and enhanced enforcement campaigns target information about child safety seats and child automobile safety to an entire community, usually geographic in nature. These campaigns use mass media; information and publicity; safety seat displays in public sites to promote use; and special enforcement strategies such as checkpoints, dedicated law enforcement officials, or alternative penalties (e.g., informational warnings instead of citations). Effective community-wide information and enhanced enforcement campaigns can complement and build on the benefit provided by child safety seat laws.

#### Reviews of evidence

##### Effectiveness

Our search identified 14 studies evaluating community-wide information and enhanced enforcement campaigns. 47-60 Descriptive information is provided in Table 3. Details of the four qualifying studies50,52-54 are available at the website (www.thecommunityguide.org).

Table 3. Community-wide information and enhanced enforcement campaigns: descriptive information about included papers

| Number of studies
| Number of studies
Papers meeting inclusion criteria | 1447-60
Papers excluded, limited execution quality | 1047-49,51,55-60
Qualifying papers | 450,52-54
Study designs
Nonrandomized group trial | 150
Time series, no concurrent comparison group | 253,54
Before-after, no concurrent comparison group | 152
Outcomes reported
Child safety set use | 450,52,53,54

The informational techniques used in the campaigns studied included paid advertisements, public service announcements, commentaries by community leaders on local television and radio programs, newspaper articles and editorials, displays of safety seats in public locations, and direct mailings of information about the importance and correct use of child safety seats. In three studies conducted in states with existing child safety seat laws,50,53,54 enhanced enforcement components included institution of checkpoints, assignment of law enforcement officers dedicated to enforcing the safety seat use law, and alternative penalties instead of citations, for example, informational warnings or vouchers to waive fines if the driver purchases a safety seat. The settings for the four campaigns in this analysis included cities, suburbs, and states. Design and implementation of campaigns involved numerous community organizations and government agencies such as public safety and public health offices, schools, advocacy organizations, and parent groups.

The median difference in safety seat use for these four studies was an increase of 12.3% (range, 3.8% to 20.8% increase) over baseline rates, measured from 1 to 6 months after the program began. The range of effect sizes followed the baseline safety seat use rates among the intervention groups across the four studies. A study with one of the lowest baseline safety seat use rates (13.6%)53 observed the smallest post-intervention effect (3.8% increase); this study was conducted in Tennessee in 1977 and 1978, early in the development of safety seat use improvement programs and in conjunction with enactment of the first mandatory child safety seat use law in the United States. A study with a higher baseline use rate (20.4%)52 observed a significant increase in use, to 34.1% (difference, 13.7% increase). Two studies with much higher baseline rates (63.4% and 65.2%, respectively)50,54 had post-intervention rates of 76.5% and 86.0%, respectively.

Three campaigns were implemented in communities with existing child safety seat laws.50,53,54 Two of these interventions50,54 included messages about enhanced enforcement or the threat of enforcement in their mass media components, and they reported increases in child safety seat use of 13.1% and 20.8%, respectively. The intervention that did not use or publicize enhanced enforcement53 reported a 4.4% increase in safety seat use.

##### Applicability

The same body of evidence was used to evaluate the applicability of these campaigns in different settings and populations. These four studies were conducted in the United States, Canada, and Australia and involved populations at all socioeconomic levels. Parents of children from birth to 11 years of age were targeted. Two studies53,54 were conducted statewide and, although the literature did not clarify the targeted populations, they likely included urban, suburban, and rural populations. No study reported the racial or ethnic makeup of the study population.

##### Other positive or negative effects

Community-wide information and enhanced enforcement campaigns can increase public awareness of child safety seat laws and the dangers of unrestrained travel. Such awareness might be an important predisposing factor for other interventions. Additional benefits of enhanced enforcement might be increased detection and arrest for alcohol-impaired driving and other offenses. No negative effects of community-wide information and enhanced enforcement campaigns were identified for evaluation in this review.

##### Economic

No studies were found that met the requirements for inclusion in a Community Guide review.18

##### Barriers to intervention implementation

Barriers to implementing community-wide information and enhanced enforcement campaigns were not identified in the literature but might include the cost of developing and disseminating public information and education material; cost of television and radio announcements; as well as enlisting the support and cooperation of the media, police departments, and other community leaders. Training enforcement personnel on the importance of enforcing child-restraint device laws and the additional burden on court systems resulting from increased law enforcement may also be barriers to implementing these programs.

##### Conclusion

According to the rules of evidence used for the Community Guide, there is sufficient scientific evidence to show that community-wide information and enhanced enforcement campaigns are effective in increasing child safety seat use.

### Distribution and education programs

Distribution and education programs provide child safety seats to parents through a loan, low-cost rental, or giveaway of an approved safety seat. All programs also include an educational component, the intensity of which varies among programs.

Parents with financial hardship or a poor understanding of the importance of acquiring and using a safety seat might be more likely to use child safety seats if they receive financial assistance and safety education. This review sought to determine the effectiveness of providing low-cost or free safety seats to parents as a means of increasing the use of safety seats.

#### Reviews of evidence

##### Effectiveness

Our search identified 17 papers on the effectiveness of distribution and education programs.14,15,61-75 Descriptive information about these papers is provided in Table 4. Details of the 10 qualifying papers14,62-64,67,69,71,72,74,75 are available at the website (www.thecommunityguide.org) and are provided as an example in the Appendix.

Table 4. Child safety seat distribution and education programs: descriptive information about included papers

| Number of studies
| Number of studies
Papers meeting inclusioncriteria | 1714,15,61-75
Papersexcluded, limited execution quality | 715,61,65,66,68,70,73
Qualifying papers | 1014,62,64,67,69,71,72,74,75
Study designs
Randomized controlled trials | 267,72
Nonrandomized group trials | 214,69
Nonrandomized individualtrials | 263,71
Time series, no concurrent comparison group | 262,64
Before-after, no concurrent comparison group | 174
Cross-sectional survey | 175
Outcomes reporteda
All fatal and nonfatal injuries | 174
Correct child safety seat use | 1314,62,64,67,69,71,72,74,75
Possession of child safety seats | 714,63,75

a Some papers reported more than one independent outcome measure.

These 10 programs provided free loaner child safety seats, low-cost rentals, or direct giveaways. In addition to providing the safety seats, all programs also gave parents information on proper usage to increase the likelihood that the safety seats would not only be used but also be used correctly. The instructional component varied considerably in terms of content of information, duration and intensity of education, methods used, and the number of methods used. For example, some programs simply provided instruction or written materials (e.g., brochures or pamphlets) on how to use the safety seat, whereas others used various educational and behavioral techniques such as active involvement in discussions, problem solving, safety seat use demonstrations, and rehearsal of skills for correct use of safety seats. Programs were implemented in hospitals, clinics, and homes and through insurance companies and were primarily targeted to parents of infants rather than older children.

Summary effects from the systematic reviews for each outcome of interest are presented in Table 5. Nine of the ten papers reported the effect of these programs on either the correct use or self-reported use of safety seats (Table 5). In addition, one paper74 evaluated a giveaway program sponsored by an automobile insurance company and observed a significant decline in injury rates among the children of policyholders (Table 5), and four14,63,71,75 evaluated the programs' effects on possession of safety seats (Table 5). Overall, all studies showed either a reduction in fatal and nonfatal injuries or an increase in child safety seat use, or both.

Table 5. Effectiveness of child safety seat distribution and education programs on various outcomes: summary effects from the body of evidence

Outcome | Number of outcome measures | Median change | Rangea
Outcome | Number of outcome measures | Median change | Rangea
All fatal or nonfatal injuries | 174 | NA | 6.4% decrease
Correct child safety seat use
Earliest post-intervention assessment (range, birth-2 years) | 1014,62,64,67,69,71,72,74,75 | 22.6% increase | 4.0%-62.3% increase
Follow-up assessment (range, 1-10 months after first assessment) | 314,71,72 | 6.0% increase | 2.1% decrease to 7.0% increase
Possession of child safety seats | 514,63,71,75 | 51.0% increase | 16.0%-93.0% increase

a When 7 or more outcome measures were available, an interquartile range is presented.

NA, Not applicable.

##### Applicability

The same body of evidence was used to evaluate the applicability of these programs in different settings and populations.14,62-64,67,69,71,72,74,75 Distribution programs were effective when implemented in hospitals and clinics, as part of postnatal home visitation, and when provided by an automobile insurance company. In addition, they were effective among urban, suburban, and rural populations and among affluent and poor populations. Studies were conducted in the United States, Canada, Australia, and Sweden with similar results.

Few studies measured baseline use rates before programs were implemented. Therefore, in populations that already have high rates of safety seat use, the level of effectiveness of distribution and education programs might be lower than the results found in this review. In addition, only three of the nine papers reported the effectiveness of such programs for children older than 9 months; the median increase in safety seat use for these three studies was 2.1% (range, 1.1% to 27.0% increase).64,69,74 Moreover, no papers reported race or ethnicity of the study population.

##### Other positive or negative effects

Because distribution programs increase the number of seats available, these programs might also result in increases in misuse of safety seats, particularly among new users. None of the identified studies measured misuse of safety seats after distribution programs, and our search did not identify any studies that looked at the likelihood of misuse after this intervention or at the issue of defective used seats.

##### Economic

No studies were found that met the requirements for inclusion in a Community Guide review.18

##### Barriers to intervention implementation

Several potential barriers to implementing child safety seat distribution and education programs are described in the literature. Implementing organizations need to consider potential liability; the initial expense for purchasing seats; cleaning and storage of child safety seats; and training of personnel to provide education and to distribute child safety seats. In addition, some child safety seats might be incompatible with certain vehicles.

##### Conclusion

Strong evidence shows the effectiveness of child safety seat distribution and education programs in improving child safety seat use, according to the rules of evidence used for the Community Guide. Additional supportive evidence indicates a decline in injury claims made to an insurance agency and increases in possession of child safety seats.

### Incentive and education programs

Incentive and education programs reward parents for obtaining and correctly using child safety seats or directly reward children for correctly using safety seats. These programs include educational components of varying intensity. If incentives and education programs are effective in increasing use in the short-term, they might also provide the impetus for some parents to continue using safety seats beyond the program.

#### Reviews of evidence

##### Effectiveness

Our search identified five reports on the effectiveness of incentive and education programs.76-80 Descriptive information on these studies is provided in Table 6. Details of the four qualifying papers76,78-80 are available at the website (www.thecommunityguide.org).

Table 6. Child safety seat incentive and education programs: descriptive information about included papers

| Number of studies
| Number of studies
Papers meeting inclusion criteria | 576-80
Papers excluded, limited execution quality | 177
Qualifying papers | 476,78-80
Study designs
Randomized group trial | 180
Time series, no concurrent comparisongroup | 376,78,79
Outcomes reported
Correct child safety seat use | 476,78,79,80

The reward used and the reward distribution method varied in the four studies. Rewards varied from inexpensive trinkets, stickers, or coupons for fast food meals or movies to relatively expensive prizes donated by community merchants. Rewards were contingent on the parent or caregiver's correct use of safety seats at the time of observation. Rewards were distributed constantly over the period of the programs (range of program implementation, 1 to 5 months). In all four programs, rewards were provided to randomly selected eligible participants. In three programs, smaller rewards were also distributed to all eligible participants.78-80

All of the programs included an educational component. This component varied considerably in terms of information content, duration and intensity of education, methods used, and the number of methods used. For example, some programs simply provided information about the reward program itself, whereas others provided information about the effectiveness of safety seats or existing laws mandating safety seat use. Some programs provided limited information (e.g., brochures or pamphlets), whereas others used various educational and behavioral techniques such as reinforcement of desired behaviors, educational videos, feedback on correct use, pledge cards, and information to parents about safety seat use. These studies included programs that were implemented in daycare centers and community-wide.

The median overall difference in safety seat use over time for all of the studies was a 9.9% increase (range, 4.8% to 36.0% increase), measured between 1 and 4.5 months after the intervention was stopped. The effectiveness of incentive programs beyond 4.5 months has not been evaluated. Baseline rates were similarly low in all four studies (median, 25.9%; range, 11.37% to 48.0%).

##### Applicability

The same body of evidence was used to evaluate the applicability of these programs in different settings and populations. Incentive and education programs were implemented in daycare centers and community-wide among a variety of target populations (children and parents of children aged 6 months to 12 years, all socioeconomic groups, urban and rural populations, white and African-American populations) with similar positive effects.

##### Other positive or negative effects

None of the identified studies measured safety seat misuse as a result of incentive and education programs in the population, and no other studies of the likelihood of misuse with this intervention were identified in the literature.

##### Economic

No studies were found that met the requirements for inclusion in a Community Guide review.18

##### Barriers to intervention implementation

Barriers to implementation of incentive and education programs were not identified in the literature but might include the cost of purchasing incentive rewards; maintaining appropriate schedules of reinforcement; training of personnel to provide the education component; and garnering support of schools, daycare centers, and other sites to sponsor incentive and education programs.

##### Conclusion

Sufficient scientific evidence exists to conclude that incentive and education programs are effective in increasing child safety seat use in the short term (i.e., 1 to 4 months), according to the rules of evidence used for the Community Guide.

### Education-only programs

Education-only programs provide information about the use of child safety seats and relevant skills to parents, children, or professional groups. Giving information to people provides the basic foundation for moving them toward behavior change such as performing new skills (e.g., routinely restraining children in safety seats) and enacting new policies (e.g., implementing hospital policies to discharge infants only if the parent uses a child safety seat). Provision of information is a central and necessary component of interventions such as community campaigns, distribution programs, and incentive programs.

#### Distinction between education-only interventions and counseling

In the Guide to Clinical Preventive Services, the U.S. Preventive Services Task Force recommends that clinicians counsel parents and children about the use of motor vehicle child safety seats.81 To complement this recommendation without overlap, we defined education-only programs for this review as any program designed to provide information about child safety seats other than those involving one-on-one counseling of a patient by a primary care clinician. All of the papers reviewed by the U.S. Preventive Services Task Force were considered for our systematic review; several were subsequently excluded because the intervention was limited to one-on-one clinician counseling of patients. The remaining papers were categorized according to the intervention's primary focus (i.e., educational or distribution program); thus, some papers are included in this review of educational programs,82-84 whereas other papers are included in the review of evidence for distribution programs.14,71,72

#### Reviews of evidence

##### Effectiveness for different target populations

The effectiveness of education-only programs directed toward parents, children, and professional groups are discussed below.

##### Education-only programs for parents

Of 11 studies identified,36,82-46 three had adequate quality of execution and were included in the body of evidence.85-87 One study reported a randomized clinical trial,85 one a nonrandomized clinical trial,87 and one used a before-after design.86 All three studies evaluated how perinatal education-only programs affected the correct use of child safety seats. None of the studies found that these programs significantly increased the proportion of correct use at the time of discharge from the hospital (median, 2.0% increase; range, 2% decrease to 10.9% increase). Baseline safety seat use rates varied considerably among the three studies (median, 63.9%; range, 8% to 94%).

##### Education-only programs for children

Of four studies identified,88,92-94 one had adequate quality of execution and was included in the body of evidence.92 This study reported a before-after design that evaluated the effect of the educational program on the use of child safety seats. Arneson et al.92 conducted a 5-day educational program, "Riding with Bucklebear," with children aged 2.5 to 5 years in a preschool setting. Knowledge scores about how to get into a child safety seat and secure it correctly increased significantly among the children from before to after the intervention (t=3.6; p=0.002), but safety seat use did not increase significantly (12% increase; p=0.33; baseline rate not stated).

##### Education-only programs for professional groups

Two studies were identified, 95,96 both with adequate quality of execution. One study reported a nonrandomized group trial,95 the other reported a before-after design.96 The two studies were done in different professional groups and, therefore, evaluated the effect of professional education on different outcomes. Wolf et al.96 evaluated a program that targeted nursing or obstetrical directors at all Nebraska hospitals that offer newborn delivery services; participants were trained to develop policies and interventions for perinatal women about the use of child safety seats. The study found significant increases from before to after the intervention in the proportion of hospitals with written policies for newborns regarding child safety seats (baseline 25.9%; 62.3% increase; p<0.001), hospitals with short-term loan programs available (baseline 58.8%; 14.1% increase; p<0.05), and hospitals with patient education programs available (baseline 51.2%; 44.1% increase; p<0.0001). Lavelle et al.95 conducted training for police officers in one community in Colorado and measured rates of enforcement of Colorado's mandatory child safety seat use law compared with rates of enforcement in a comparison community. Officers in the intervention community increased the number of citations issued from 0 to 10 per month to 10 to 20 per month 6 months after the intervention was completed. The number of citations in the comparison community did not change.

##### Other positive or negative effects

Educational programs for parents might increase their knowledge about child safety seat laws and the effectiveness of safety seats, and improved knowledge might be an important predisposing factor for other interventions. Improper installation of the safety seat in the vehicle, improper harnessing of the child into the safety seat, or improper placement of a rear-facing infant safety seat in a front passenger seat are examples of the safety seat misuse that can occur when parents who have not previously used safety seats receive inadequate education about the devices. No study identified higher rates of misuse between intervention and comparison populations, and no other studies of the likelihood of misuse were identified in the literature.

Educational programs might increase children's knowledge about the benefits of using safety seats or safety belts, and this increased knowledge might be a predisposing factor for other interventions. No study identified increased misuse of child safety seats among people who received the intervention, and none proposed potential harms of educational programs for safety belt use among older children.

Educational programs for professional groups might increase their knowledge about the importance of advocating for safety seat use among children. Their advocacy might, in turn, be a predisposing factor for other interventions. No harms of educational programs for professional groups were proposed in the literature.

##### Applicability

The body of evidence used to evaluate the applicability of these programs in different settings and populations was the same as that used to evaluate effectiveness. The six studies included in this review were implemented in hospitals, preschools, and work sites. Within these settings, interventions were aimed at specific target populations (parents, children, or professional groups). Educational programs for parents were only directed toward improving safety seat use among infants; none examined the effect of education for parents of older children. Urban and suburban populations of low, middle, and upper socioeconomic status were represented in some of the studies. No studies reported the racial or ethnic makeup of the study populations.

##### Economic

Evidence about economic effectiveness was not collected for this intervention because effectiveness was not established.

##### Barriers to intervention implementation

Evidence about barriers was not collected for this intervention because effectiveness was not established.

##### Conclusion

Available studies provide insufficient evidence to assess the effectiveness of education-only programs in improving knowledge about or use of child safety seats. However, education is a central component of most other effective interventions. Until more and better information becomes available, communities might choose to make decisions about the use of education-only programs on grounds other than evidence of direct effects from available studies.

## Results. Part II. Research Issues

### Effectiveness

For all five interventions, the team identified key research issues that had not been answered in the systematic review process. These research issues were grouped by the types of evidence sought. The team identified sufficient or strong evidence of effectiveness for four interventions (i.e., child safety seat laws, community-wide information and enhanced enforcement campaigns, distribution programs, and incentive programs). However, several important research issues about the effectiveness of these interventions remain.

1. Does effectiveness of the intervention change when specific elements are changed? For example, Does the effectiveness of child safety seat laws vary depending on the requirements of different state laws?Does effectiveness of laws vary depending on the intensity and visibility of regular enforcement in the state?Would the threat of being charged with contributory negligence if an unrestrained child is killed or injured in a motor vehicle crash change the effectiveness of the law?What role does information about laws play in compliance rates?Are distribution programs sponsored by medical care organizations more or less effective than programs implemented by other organizations (e.g., insurance companies or community organizations)?Are low-cost rental programs any more or less effective than free loan programs?Are different incentives needed for different devices (e.g., infant safety seats, child seats, booster seats, safety belts)?What is the relative effectiveness of different incentives (e.g., direct rewards related to restraint use vs chances to win prizes)?
2. What is the long-term effectiveness of each intervention? For example, How can the effectiveness of a child safety seat law be maintained over time?Can incentive programs improve long-term use of child safety seats? If so, what kind of reward schedule and distribution method is necessary to maintain positive effects?
3. How effective are various combinations of these four interventions? For example, Does enhanced enforcement provide marginal benefit to that provided by legislation?Do hospital discharge policies requiring that newborns be restrained in an approved device increase the effectiveness of distribution programs?

Because the effectiveness of education alone has not been established, basic research questions remain. For example,

- What amount and quality of content are necessary to improve knowledge, attitudes, and behaviors?
- What are appropriate educational contents and methods for delivery to children at various developmental stages?
- What are the appropriate outcomes to measure when educating young children about the use of child safety seats?
- Is education alone effective to: - increase parental use of child safety seats? - increase children's independent use of child safety seats? - increase enforcement of child safety seat laws by law enforcement officials? - encourage hospital personnel to develop and enforce policies about child safety seat use?

### Other positive and negative effects

The studies included in the reviews did not measure other positive and negative effects of the interventions. For all five interventions, research is needed to determine whether each intervention is likely to either increase or reduce misuse of child safety seats. Research is also needed to determine the role of community-wide or individual education in facilitating the effectiveness of other interventions (e.g., legislation, loaner programs).

### Applicability

Each of the effective interventions should be applicable in most of the relevant target populations and settings. However, differences in the effectiveness of each intervention for specific subgroups of the population could not be determined. Several questions about the applicability of these interventions in settings and populations other than those studied remain. For example,

- Are these interventions equally effective in all populations within a state (e.g., racial and ethnic minorities, high- and low-income populations, or behavior change-resistant populations)?
- How must the content and methods of the educational components of interventions be altered to work in different populations?
- Are these interventions effective in populations that already have high baseline safety seat use rates?
- Do programs targeted at parents of infants improve the rate at which parents buy or use child safety seats for children older than 1 year?
- Are incentive programs effective in settings other than those studied (e.g., state motor vehicle inspection stations) or when implemented by other organizations (e.g., community groups or local businesses)?

### Economic evaluations

The team did not identify any economic evaluation meeting Community Guide standards for these interventions. Thus, basic economic research must still be conducted:

- What is the cost of interventions to increase the use of child safety seats?
- Are interventions to increase the use of child safety seats cost-saving?
- What is the return on investment of interventions to increase child safety seat use?

## Discussion

Systematic literature reviews are particularly useful for creating guidelines. The Task Force on Community Preventive Services (the Task Force) has done this by using the evidence from these systematic reviews to make recommendations about the use of the interventions.97 Systematic reviews are also useful for identifying gaps in our knowledge base. The research questions provided in this article should be used to guide future research, both by government agencies and foundations in allocating research funding and by academic and other research organizations in determining research priorities.

Dissemination of these findings is ongoing through federal and state government agencies, advocacy organizations, and other groups with missions that include reducing child motor vehicle occupant injuries. Implementation advice for these interventions is available from several organizations, including the National Highway Traffic Safety Administration (www.nhtsa.gov), the National Center for Injury Prevention and Control of the Centers for Disease Control and Prevention (www.cdc.gov/ncipc), and the National SAFE KIDS Campaign (www.safekids.org).

An important implementation issue regarding distribution and education programs has arisen since the studies in this review were conducted. Because the integrity of child safety seats can be compromised in a crash, seats returned to a distribution and education program should not be lent to others because there can be no guarantee that they were not involved in a crash. Therefore, when implementing child safety seat distribution and education programs, only new, unused seats should be provided to all recipients.

These interventions are aimed at children aged birth to 4 years and their parents. All 50 states require children in this age group to be properly restrained while riding in motor vehicles. An accompanying article in this supplement98 addresses interventions to improve the use of safety belts among teenagers and adults. A clear gap in these two sets of reviews and in the Task Force's recommendations is for children who are too old or too large to sit in child safety seats but who are too small to wear safety belts without the use of booster seats (generally children aged 4 to 8 years).99 The literature base regarding the efficacy of booster seats, and particularly for population-based interventions to improve their use, is still emerging. Future updates of these reviews and recommendations should address this vulnerable population.

Systematic reviews are limited to the information published in the existing studies. In the present reviews, for example, no studies discriminated between correct and incorrect use of child safety seats. Although some studies evaluated correct use only, they neither estimated incorrect use nor discussed how to correct mistakes in child safety seat installation or child restraint. Because estimates of misuse of child safety seats are so high, it is imperative to continue research on how to reduce misuse of child safety seats.100

Finally, these reviews did not examine positioning of children within the car. Recent evidence has clearly shown a relationship between placement of rearward-facing infant safety seats in the passenger seat of a car with an activated airbag and increased risk of death of the infant if the airbag is deployed.101 None of the studies included in the reviews examined the effect of the interventions on placement of the child safety seat in the rear seat of the car. This problem is due largely to the abundance of studies that predated either the widespread installation of airbags or the recognition of the danger of airbags to infants and children.7,102

Although numerous questions remain, evidence is available about the effectiveness of four of the five strategies we reviewed. This scientific evidence, along with the accompanying recommendations of the Task Force,97 can be a powerful tool for securing the resources and commitment required to implement these strategies.

We thank the following individuals for their contributions to this review: Erin Finley and Krista Hopkins, Research Assistants; Randy Elder, Service Fellow; Vilma G. Carande-Kulis and Mary Olufemi Alao, Economics Team; Sandra Bonzo and Joanna Taliano, Research Librarians; Kate W. Harris, Editor; our Consultation Team -- J. C. Bolen, PhD, MPH, National Center for Chronic Disease Prevention and Health Promotion, CDC, Atlanta, GA; R. D. Brewer, MD, MSPH, Nebraska Department of Health, Lincoln; S. D. Bryn, MPH, Health Resources Services Administration, Rockville, MD; F. M. Council, PhD, University of North Carolina, Chapel Hill; R. W. Denniston, MA, Substance Abuse and Mental Health Services Administration, Rockville, MD; A. C. Gielen, ScD, ScM, Johns Hopkins University, Baltimore, MD; S. Gorcowski, MA, National Highway Traffic Safety Administration, Washington, DC; C. A. Hurley, BA, National Safety Council, Washington, DC; B. H. Jones, MD, MPH, National Center for Injury Prevention and Control, CDC, Atlanta, GA; T. A. Karlson, PhD, University of Wisconsin, Madison; M. R. Kinde, MPH, Minnesota Department of Health, Minneapolis; D. W. Lawrence, MPH, RN, San Diego State University, CA; S. E. Martin, PhD, National Institute for Alcohol Abuse and Alcoholism, Rockville, MD; J. A. McKnight, PhD, National Public Service Research Institute, Landover, MD; A. D. Mickalide, PhD, CHES, National SAFE KIDS Campaign, Washington, DC; J. L. Nichols, PhD, National Highway Traffic Safety Administration, Washington, DC; L. F. Novick, MD, MPH, Onandaga County Department of Health, Syracuse, NY; F. P. Rivara, MD, MPH, University of Washington, Seattle; C. W. Runyan, PhD, MPH, University of North Carolina, Chapel Hill; R. J. Smith, MS, Health Resources and Services Administration, Rockville, MD; P. F. Waller, PhD, University of Michigan, Ann Arbor; A. F. Williams, PhD, Insurance Institute for Highway Safety, Arlington, VA; and our Abstraction Team -- A. Dellinger, PhD, National Center for Injury Prevention and Control, CDC, Atlanta, GA; I. Fischer, MPH, St. Louis Children's Hospital, St. Louis, MO; D. W. Lawrence, MPH, RN, San Diego State University, CA; J. Oh, MD, MPH, Harrisburg, PA; K. Quinlan, MD, MPH, University of Chicago, Pritzker School of Medicine, Chicago, IL; L. Rhodes, MPA, MPH, National Center for Chronic Disease Prevention and Health Promotion, CDC, Atlanta, GA; R. A. Shults, PhD, MPH, National Center for Injury Prevention and Control, CDC, Atlanta, GA; D. Sudakin, MD, MPH, Oregon State University, Corvallis.

## References and Notes

[1] Centers for Disease Control and Prevention, National Center for Health Statistics, 1998 mortality data. (2000) Hyattsville, MD: National Center for Health Statistics.
[2] National Highway Traffic Safety Administration. Traffic safety facts 1999: children. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 2000. DOT HS 809 087.
[3] National Highway Traffic Safety Administration. Buckle Up America: the presidential initiative for increasing seat belt use nationwide. First report to Congress. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1998. DOT HS 808 667.
[4] National Highway Traffic Safety Administration,. Research note: revised estimates of child restraint effectiveness. (1996). Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration. [pmcid: 190016].
[5] Children's Safety Network,. Child safety seats: how large are the benefits and who should pay?. (1997). Childhood injury: cost & prevention facts. Landover, MD: Children's Safety Network: Economics and Insurance Resource Center. [pmcid: 176006].
[6] National Highway Traffic Safety Administration. Traffic safety facts, 1999: a compilation of motor vehicle crash data from the Fatality Analysis Reporting System and the General Estimates System. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 2000. DOT HS 809 100.
[7] Centers for Disease Control and Prevention, Air-bag associated fatal injuries to infants and children riding in front passenger seats-United States MMWR 1995, 4445:845 847 7476837
[8] Johnston C., Rivara F.P. and Soderberg R. Children in car crashes: analysis of data for injury and use of restraints. Pediatrics. 1994,;93:960-965. [pmid: 8190584].
[9] Taft C.H., Mickalide A.D. and Taft A.R. Child passengers at risk in America: a national study of car seat misuse. (1999). Washington, DC: National SAFE KIDS Campaign. [pmcid: 325679].
[10] Braver ER, Whitfield RA, Ferguson SA. Risk of death among child passengers in front and rear seating positions. Warrendale, PA: Society of Automotive Engineers, 1997. SAE Technical Paper No 973298.
[11] Hazinski M.F., Eddy V.A. and Morris J.A. Jr. Children's traffic safety program: influence of early elementary school safety education on family seat belt use. J Trauma. 1995,;39:1063-1068. [pmid: 7500394].
[12] National Highway Traffic Safety Administration,. National Occupant Protection Use Survey: controlled intersection study Research note. (1995). Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, National Center for Statistics and Analysis. [pmcid: 441483].
[13] National Highway Traffic Safety Administration. Rural and urban crashes: a comparative analysis. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1996. DOT HS 808 450.
[14] Robitaille Y., Legault J., Abbey H. and Pless I.B. Evaluation of an infant car seat program in a low-income community. Am J Dis Child. 1990,;144:74-78. [pmid: 2294722].
[15] Louis B. and Lewis M. Increasing car seat use for toddlers from inner-city families. Am J Public Health. 1997,;87:1044-1045. [pmid: 9224195].
[16] National Highway Traffic Safety Administration,. Strategies to increase the use of child safety seats by low-income families: a report to the Committees on Appropriations, U.S. House of Representatives, U.S. Senate. (1991) Washington, DC: U.S Department of Transportation, National Highway Traffic Safety Administration.
[17] the Task Force on Community Preventive Services, Briss P.A., Zaza S. and Pappaioanou M. et al. Developing an evidence-based Guide to Community Preventive Services—methods Am J Prev Med 2000, 18suppl 1:35 43 10806978
[18] the Task Force on Community Preventive Services, Zaza S., Carande-Kulis V.G. and Sleet D.A. et al. Methods for conducting systematic reviews of the evidence of effectiveness and economic efficiency of interventions to reduce injuries to motor vehicle occupants Am J Prev Med 2001, 21suppl 4:23 30 11691559
[19] the Task Force on Community Preventive Services, Truman B.I., Smith-Akin C.K. and Hinman A.R. et al. Developing the Guide to Community Preventive Services—overview and rationale Am J Prev Med 2000, 18suppl 1:18 26
[20] the Task Force on Community Preventive Services, Carande-Kulis V.G., Maciosek M.V. and Briss P.A. et al. Methods for systematic reviews of economic evaluations for the Guide to Community Preventive Services Am J Prev Med 2000, 18suppl 1:75 91 10806980
[21] the Task Force on Community Preventive Services, Zaza S., Wright-de Aguero L. and Briss P.A. et al. Data collection instrument and procedure for systematic reviews in the Guide to Community Preventive Services Am J Prev Med 2000, 18suppl 1:44 74 10806979
[22] Ain K.B., Barrall D.T., Perez R.G. and Ward H.A. Patterns of automotive safety restraint use in Rhode Island: impact of the child passenger restraint law. R I Med J. 1981,;64:515-519. [pmid: 6947373].
[23] O'Brien JF. Child safety restraint study: a study of the effects of child safety restraint legislation on the incidence and severity of motor vehicle accident injuries to children six years of age and younger (based on 1980-1982 and 1984-1985 accidents). Albany, NY: New York State Department of Motor Vehicles, 1986. PB87-183554.
[24] Agent KR. Usage rates and effectiveness of safety belts and child safety seats in Kentucky, 1988. Lexington, KY: Kentucky Transportation Center, College of Engineering, University of Kentucky, 1988. KTC-88-6.
[25] Agran PF, Dunkle DE, Winn DG. The effects of safety seat legislation on pediatric trauma. Washington, DC: U.S. Department of Transportation, Office of University Research, 1986. DOT/OST/P-34/86-044.
[26] Agran P.F., Dunkle D.E. and Winn D.G. Effects of legislation on motor vehicle injuries to children. Am J Dis Child. 1987,;141:959-964. [pmid: 3618571].
[27] Evans W.N. and Graham J.D. An estimate of the lifesaving benefit of child restraint use legislation. J Health Econ. 1990,;9:121-142. [pmid: 10107498].
[28] Guerin D. and MacKinnon D.P. An assessment of the California child passenger restraint requirement. Am J Public Health. 1985,;75:142-144. [pmid: 3966618].
[29] Rock S.M. Impact of the Illinois child passenger protection act: a retrospective look. Accid Anal Prev. 1996,;28:487-492. [pmid: 8870775].
[30] Hall WL. The North Carolina child passenger protection law: implementation and evaluation, July 1982-June 1985. Chapel Hill, NC: University of North Carolina Highway Safety Research Center, 1985. 85-04-LE-304-01.
[31] Montague RB. The introduction of child safety seat legislation in Virginia: types and levels of community response and effects on automobile accident statistics. Washington, DC: U.S. Department of Transportation, Office of University Research, 1984. DOT/OST/P-34/85/024.
[32] Muller A. Is the Oklahoma child restraint law effective?. Am J Public Health. 1986,;76:1251-1252. [pmid: 3752336].
[33] Wagenaar A.C. Mandatory child restraint laws: impact on childhood injuries due to traffic crashes. J Safety Res. 1985,;16:9-21.
[34] Wagenaar AC, Maybee RG, Sullivan KP. Michigan's compulsory restraint use policies: effects on injuries and deaths. Ann Arbor: University of Michigan Transportation Research Institute, 1987. UMTRI 87-10.
[35] Williams A.F. and Wells J.K. The Tennessee child restraint law in its third year. Am J Public Health. 1980,;71:163-165.
[36] Alvarez J. and Jason L.A. The effectiveness of legislation, education, and loaners for child safety in automobiles. J Community Psychol. 1993,;21:280-284.
[37] Margolis L.H., Wagenaar A.C. and Liu W. The effects of a mandatory child restraint law on injuries requiring hospitalization. Am J Dis Child. 1988,;142:1099-1103. [pmid: 3177307].
[38] Partyka SC. Effect of child occupant protection laws on fatalities. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1989. DOT HS 807 453.
[39] Rood DH, Kraichy PP. Evaluation of New York state's mandatory occupant restraint law.Volume 3: observational surveys of safety restraint use by children in New York State. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1986. DOT HS 806 972.
[40] Seekins T., Fawcett S.B. and Cohen S.H. et al. Experimental evaluation of public policy: the case of state legislation for child passenger safety. J Appl Behav Anal. 1988,;21:233-243. [pmid: 3198544].
[41] Sewell C.M., Hull H.F., Fenner J., Graff H. and Pine J. Child restraint law effects on motor vehicle accident fatalities and injuries: the New Mexico experience. Pediatrics. 1986,;78:1079-1084. [pmid: 3786033].
[42] Wagenaar A.C., Webster D.W. and Maybee R.G. Effects of child restraint laws on traffic fatalities in eleven states. J Trauma. 1987,;27:726-732. [pmid: 3612844].
[43] Williams A.F. and Wells J.K. Evaluation of the Rhode Island child restraint law. Am J Public Health. 1981,;71:742-743. [pmid: 7246844].
[44] Cunningham JL, Hughes EC, Philpot JW, Pentz CA. Parents' knowledge, attitudes and behavior about child passenger safety. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1981. DOT HS 805 947.
[45] Wagenaar A.C. and Webster D.W. Preventing injuries to children through compulsory automobile safety seat use. Pediatrics. 1986,;78:662-672. [pmid: 3763278].
[46] Williams A.F. Evaluation of the Tennessee child restraint law. Am J Public Health. 1979,;69:455-458. [pmid: 434275].
[47] Gielen A.C. and Radius S. Project KISS (Kids in Safety Seats): educational approaches & evaluation measures. Health Educ. 1984,;15:43-47.
[48] National Highway Traffic Safety Administration. Evaluation of child safety seat enforcement strategies. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1989. DOT HS 807 479.
[49] Bowler MA, Torpey S. Community road safety program (Latrobe Valley). First 18 months of operation. Victoria, Australia: Road Traffic Authority, 1988. GR/88/3.
[50] Decina L.E., Temple M.G. and Dorer H.S. Increasing child safety-seat use and proper use among toddlers. Evaluation of an enforcement and education program. Accid Anal Prev. 1994,;26:667-673. [pmid: 7999211].
[51] McCooey E.B. and Feun L. TLC—tender loving care for tender living cargo: an innovative approach to child passenger safety in a local health department. Health Educ. 1984,;15:48-51.
[52] Pless I.B., Stulginskas J. and Zvagulis I. Observed effects of media campaigns on restraint use. Can J Public Health. 1986,;77:28-32. [pmid: 3697888].
[53] Heathington KW, Philpot JW, Perry RL. Impact of legislation and public information and education on child passenger safety. Transportation Res Rec. 1982;:62-70.
[54] Lane JM, Milne PW, Wood HT. Evaluation of a successful rear seat belt publicity campaign. The 12th ARRB Conference, Hobart, Tasmania, August 27-31, 1984. pp. 13-21.
[55] Cox RG, Fleming D. Selective enforcement campaign to increase the use of restraints by children in motor vehicles. Sydney, Australia: National Roads and Motorists' Association, 1981. UMTRI 47823.
[56] Hall WL, Orr BT, Suttles DT, et al. Progress report on increasing child restraint usage through local education and distribution programs. Chapel Hill, NC: University of North Carolina Highway Safety Research Center, 1983. UNC/HSRC-83-10-2.
[57] Boughton CJ, Johnston IR. The effects of radio and press publicity on the safe carriage of children in cars. Warrendale, PA: Society of Automotive Engineers, Inc., 1979. 790075.
[58] Land G., Romeis J.C., Gillespie K.N. and Denny S. Missouri's Take a Seat, Please! and program evaluation. J Public Health Manag Pract. 1997,;3:52-59.
[59] Geddis D.C. How children travel in cars in New Zealand. N Z Med J. 1982,;95:740-742. [pmid: 6959030].
[60] Wheeler YCH. Restraint use attitudes and knowledge prior to and following the 1993 rear seat child restraint use campaign in NSW amongst three non-English speaking background communities. New South Wales, Australia: Roads and Traffic Authority (NSW), Road Safety Bureau, 1994. Research Note RN 15/94.
[61] Berger L.R., Saunders S., Armitage K. and Schauer L. Promoting the use of car safety devices for infants: an intensive health education approach. Pediatrics. 1984,;74:16-19. [pmid: 6739211].
[62] Colletti R.B. Longitudinal evaluation of a statewide network of hospital programs to improve child passenger safety. Pediatrics. 1986,;77:523-529. [pmid: 3960621].
[63] Culler CJ, Cunningham JL. Compliance with the child passenger protection law: effects of a loaner program for low-income mothers. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration, 1980. DOT HS 805 801.
[64] Geddis D.C. and Appleton I.C. Establishment and evaluation of a pilot child car seat rental scheme in New Zealand. Pediatrics. 1986,;77:167-172. [pmid: 3945529].
[65] Hletko PJ, Hletko J, Shelness A, Nyberg J. The effect of a toddler/child restraint device rental program on observed correct use. 27th Annual Conference Proceedings, American Association for Automotive Medicine, October 3-6, 1983. pp. 115-125.
[66] Hletko PJ, Hletko J, Shelness A, Nyberg J. The effect of an in-hospital maternity education program on observed correct crash restraint device use. 26th Annual Proceedings, American Association for Automotive Medicine, October 4-6, 1982. pp. 219-32.
[67] Hletko P.J., Robin S.S., Hletko J.D. and Stone M. Infant safety seat use: reaching the hard to reach. Am J Dis Child. 1987,;141:1301-1304. [pmid: 3687872].
[68] Jarmark S, Ljungblom BA, Turbell T. Infant carriers—a trial in two counties. Linkoeping, Sweden: National Swedish Road & Traffic Research Institute, 1988. 316A HS-040 518.VTI Rapport.
[69] Lindqvist K.S. Does the use of child safety seats increase as the result of loan schemes?. Accid Anal Prev. 1993,;25:421-429. [pmid: 8357455].
[70] Nichol K.P. and Cooney C.E. The impact of a hospital-based educational loaner infant car seat program on infant car seat usage in a community. Travel Med Int. 1984,;2:155-158.
[71] Reisinger K.S. and Williams A.F. Evaluation of programs designed to increase the protection of infants in cars. Pediatrics. 1978,;62:280-287. [pmid: 704196].
[72] Christophersen E.R. and Sullivan M.A. Increasing the protection of newborn infants in cars. Pediatrics. 1982,;70:21-25. [pmid: 7088627].
[73] Moyes C.D., Tustin R.J., McLean J.F. and Turner G.R. Changing patterns in child restraint use. N Z Med J. 1984,;97.
[74] Saalberg JH, Morrison AJ. Restraint use and injury experience. In: Evaluation of the League General Insurance Company child safety seat distribution program; DOT HS 806 253. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration. 1982::22-47. [pmcid: 272288].
[75] Saalberg JH, Morrison AJ. Household survey. In: Evaluation of the League General Insurance Company child safety seat distribution program; DOT HS 806 253. Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration. 1982::63-120. [pmcid: 426146].
[76] Foss R.D. Evaluation of a community-wide incentive program to promote safety restraint use. Am J Public Health. 1989,;79:304-306. [pmid: 2464950].
[77] Liberato C.P., Eriacho B., Schmiesing J. and Krump M. SafeSmart safety seat intervention project: a successful program for the medically-indigent. Patient Educ Couns. 1989,;13:161-170.
[78] Roberts M.C. and Turner D.S. Rewarding parents for their children's use of safety seats. J Pediatr Psychol. 1986,;11:25-36. [pmid: 3958866].
[79] Roberts M.C. and Layfield D.A. Promoting child passenger safety: a comparison of two positive methods. J Pediatr Psychol. 1987,;12:257-271. [pmid: 3612427].
[80] Stuy M., Green M. and Doll J. Child care centers: a community resource for injury prevention. J Dev Behav Pediatr. 1993,;14:224-229. [pmid: 8408664].
[81] U.S. Preventive Services Task Force,. Guide to Clinical Preventive Services: report of the U.S. Preventive Services Task Force. (1996) (2nd ed.) Baltimore: Williams &Wilkins.
[82] Allen D.B. and Bergman A.B. Social learning approaches to health education: utilization of infant auto restraint devices. Pediatrics. 1976,;58:323-328. [pmid: 60736].
[83] Greenberg L.W. and Coleman A.B. A prenatal and postpartum safety education program: influence on parental use of infant car restraints. J Dev Behav Pediatr. 1982,;3:32-34. [pmid: 7076861].
[84] Miller J.R. and Pless I.B. Child automobile restraints: evaluation of health education. Pediatrics. 1977,;59:907-911. [pmid: 68458].
[85] Christophersen E.R., Sosland-Edelman D. and LeClaire S. Evaluation of two comprehensive infant car seat loaner programs with 1-year follow-up. Pediatrics. 1985,;76:36-42. [pmid: 4011356].
[86] Goebel J.B., Copps T.J. and Sulayman R.F. Infant car seat usage. Effectiveness of a postpartum educational program. JOGN Nurs. 1984,;13:33-36. [pmid: 6560047].
[87] Tietge N.S., Bender S.J. and Scutchfield F.D. Influence of teaching techniques on infant car seat use. Patient Educ Couns. 1987,;9:167-175. [pmid: 10282837].
[88] Bowman J.A., Sanson-Fisher R.W. and Webb G.R. Interventions in preschools to increase the use of safety restraints by preschool children. Pediatrics. 1987,;79:103-109. [pmid: 3797156].
[89] Chang A., Hearey C.D., Gallagher K.D., English P. and Chang P.C. Promoting child passenger safety in children served by a health maintenance organization. Patient Educ Couns. 1989,;13:297-307. [pmid: 10293483].
[90] Geddis D.C. and Pettengell R. Parent education: Its effect on the way children are transported in cars. N Z Med J. 1982,;95:314-316. [pmid: 6954391].
[91] Goodson J.G., Buller C. and Goodson W.H. III. Prenatal child safety education. Obstet Gynecol. 1985,;65:312-315. [pmid: 3974957].
[92] Arneson S.W. and Triplett J.L. Riding with Bucklebear: an automobile safety program for preschoolers. J Pediatr Nurs. 1990,;5:115-122. [pmid: 2324926].
[93] Chang A., Dillman A.S., Leonard E. and English P. Teaching car passenger safety to preschool children. Pediatrics. 1985,;76:425-428. [pmid: 4034302].
[94] Williams A.F., Wells J.K. and Ferguson S.A. Development and evaluation of programs to increase proper child restraint use. J Safety Res. 1997,;28:69-73.
[95] Lavelle J.M., Hovell M.F., West M.P. and Wahlgren D.R. Promoting law-enforcement for child protection: a community analysis. J Appl Behav Anal. 1992,;25:885-892. [pmid: 1478911].
[96] Wolf D., Tomek D.J., Stacy R.D., Corbin D.E. and Greer D.L. Promoting hospital discharge of infants in safety seats. J Community Health. 1995,;20:345-357. [pmid: 7593740].
[97] Task Force on Community Preventive Services, Recommendations to reduce injuries to motor vehicle occupants: increasing child safety seat use, increasing safety belt use, and reducing alcohol-impaired driving Am J Prev Med 2001, 21suppl 4:16 22 11691558
[98] the Task Force on Community Preventive Services, Dinh-Zarr T.B., Sleet D.A. and Shults R.A. et al. Reviews of evidence regarding interventions to increase use of safety belts Am J Prev Med 2001, 21suppl 4:48 65
[99] Centers for Disease Control and Prevention, Motor-vehicle occupant fatalities and restraint use among children aged 4-8 years. United States, 1994-1998 MMWR 2000, 4907:135 137 10765893
[100] Centers for Disease Control and Prevention, Improper use of child safety seats—Kentucky, 1996 MMWR 1998, 4726:541 544 9675015
[101] National Highway Traffic Safety Administration. Children and air bags. 2001. Available at: www.nhtsa.dot.gov/people/injury/airbags/Airbags.html. Accessed March 9, 2001.
[102] Centers for Disease Control and Prevention, Notice to readers. Approval of installation of air bag on-off switches for certain motor-vehicle owners MMWR 1997, 4646:1098 1099

## Appendix: Studies Measuring the Effectiveness of Child Safety Seat Distribution Programs