# Motor Vehicle Occupant Injury

Foreword: Note from the Surgeon General

Public Health's Contribution to Motor Vehicle Injury Prevention

Discussion: Motor vehicle occupant injury prevention: the states' perspective

Research As an Advocate's Toolkit to Reduce Motor Vehicle Occupant Deaths and Injuries

The effectiveness review trials of Hercules and some economic estimates for the stables

The Guide to Community Preventive Services: A Public Health Imperative

Recommendations to reduce injuries to motor vehicle occupants Increasing child safety seat use, increasing safety belt use, and reducing alcohol-impaired driving

Methods for Conducting Systematic Reviews of the Evidence of Effectiveness and Economic Efficiency of Interventions to Reduce Injuries to Motor Vehicle Occupants

Reviews of evidence regarding interventions to increase use of child safety seats

Reviews of Evidence Regarding Interventions to Increase the Use of Safety Belts

Reviews of Evidence Regarding Interventions to Reduce Alcohol-Impaired Driving