# Subject Index

- access to places for physical activity, creation of
- [Chapter 4] [Chapter 5]

- camp setting, DSME in
- [Chapter 1] [Chapter 3]

case management in diabetes

- recommendations
- [Chapter 1]

- reviews of evidence
- [Chapter 2]

classroom-based health education

- physical activity and
- [Chapter 4] [Chapter 5]

- television viewing and video game playing, reduction in
- [Chapter 4] [Chapter 5]

- college-based health education and physical education
- [Chapter 4] [Chapter 5]

commentary

- diabetes
- [Front Matter] [Front Matter] [Front Matter]

- physical activity
- [Front Matter] [Front Matter]

- community gathering places, DSME in
- [Chapter 1] [Chapter 3]

- community-wide campaigns, PA and
- [Chapter 4] [Chapter 5]

- Diabetes Control and Complications Trial (DCCT)
- [Chapter 3]

- Diabetes Prevention Program (DPP)
- [Front Matter] [Front Matter]

diabetes self-management education (DSME)

- commentary
- [Front Matter]

- recommendations
- [Chapter 1]

- reviews of evidence
- [Chapter 3]

- evidence-based medicine
- [Chapter 1] [Chapter 2] [Chapter 3] [Chapter 4] [Chapter 5]
- translating into practice
- [Front Matter]

- family-based social support, PA and
- [Chapter 4] [Chapter 5]

- fitness, physical
- [Chapter 4]

- Foreword, diabetes and physical activity
- [Front Matter]

- health behavior change programs, individually-adapted, PA and
- [Chapter 4] [Chapter 5]

- home, DSME in
- [Chapter 1] [Chapter 3]

- informational outreach activities, PA and
- [Chapter 4] [Chapter 5]

- mass media campaigns, PA and
- [Chapter 4] [Chapter 5]

physical activity (PA), interventions to increase

- commentary
- [Front Matter]

- diabetes and
- [Front Matter] [Front Matter]

- recommendations
- [Chapter 4]

- reviews of evidence
- [Chapter 5]

- point of decision prompts, PA and
- [Chapter 4] [Chapter 5]

- school-based physical education
- [Chapter 4] [Chapter 5]

- school personnel, education of, about diabetes
- [Chapter 1] [Chapter 3]

- social support interventions in community settings, PA and
- [Chapter 4] [Chapter 5]

- worksite, DSME in
- [Chapter 1] [Chapter 3]