# Author Index

- Anderson, R.M.
- [Front Matter]

- Blair SN
- [Front Matter]

- Briss, P
- [Chapter 2] [Chapter 3]

- Brownson RC
- [Chapter 5]

- Carande-Kulis VG
- [Chapter 2] [Chapter 3]

- Caspersen CJ
- [Chapter 2] [Chapter 3]

- Corso P
- [Chapter 5]

- Dunn AL
- [Front Matter]

- Engelgau MM
- [Chapter 2] [Chapter 3]

- Funnell MM
- [Front Matter]

- Garfield S
- [Chapter 2] [Chapter 3]

- Glasgow RE
- [Chapter 2] [Chapter 3]

- Heath GW
- [Chapter 5]

- Howze EH
- [Chapter 5]

- Isham G
- [Chapter 2] [Chapter 3]

- Jack Jr. L
- [Chapter 2] [Chapter 3]

- Kahn EB
- [Chapter 5]

- Kriska A
- [Front Matter]

- McCulloch D
- [Chapter 2] [Chapter 3]

- McGinnis JM
- [Front Matter]

- Nichols PJ
- [Chapter 2] [Chapter 3]

- Norris SL
- [Chapter 2] [Chapter 3]

- Powell KE
- [Chapter 5]

- Rajab MW
- [Chapter 5]

- Ramsey LT
- [Chapter 5]

- Snyder SR
- [Chapter 2] [Chapter 3]

- Stone EJ
- [Chapter 5]

- Task Force on Community Preventative Services
- [Chapter 1] [Chapter 2] [Chapter 3] [Chapter 4] [Chapter 5]