# Diabetes and Physical Activity

Foreword: Diabetes and physical activity: Translating evidence into action

Working toward the next generation of diabetes self-management education

Striving for a more active community: Lessons from the diabetes prevention program and beyond

Translating Evidenced-Based Physical Activity Interventions Into Practice: The 2010 Challenge

Recommendations for Healthcare System and Self-Management Education Interventions to Reduce Morbidity and Mortality from Diabetes

The Effectiveness of Disease and Case Management for People with Diabetes

Increasing Diabetes Self-Management Education in Community Settings: A Systematic Review

Recommendations to increase physical activity in communities

The effectiveness of interventions to increase physical activity: A systematic review

Author Index

Subject Index