# Guides in Spanish

1 Formas de controlar el dolor después de una operación Guía para el paciente

2 La incontinencia urinaria en los adultos

3 La prevención de las llagas por contacto: Guía para el paciente

4 Las cataratas en los adultos

5 Existen tratamientos para la depresión

6 Anemia de célula falciforme en los recién nacidos y los bebés Guía para los padres

8 Tratamientos para la inflamación (crecimiento) benigna de la próstata

9 El control del dolor causado por el cáncer

10 La angina de pecho inestable

11 La insuficiencia cardíaca

12 Cuando se acumula líquido en el oído medio de su niño

13 Lo que la mujer debe saber sobre los mamogramas (rayos-x del seno)

14 Información sobre los problemas agudos de la parte baja de la espalda

15 Tratamientos para las llagas por contacto

16 Rehabilitación después de un ataque cerebral

17 La recuperación de los problemas cardíacos a través de la rehabilitación

18 Si quiere, puede dejar de fumar

19 Primeros síintomas de la enfermedad de Alzheimer