# Guides in English

1 Pain Control after Surgery: A Patient's Guide: Consumer Guideline Number 1

2 Understanding Incontinence: A Patient's Guide: Consumer Version 2, 1996 Update

3 Preventing Pressure Ulcers: A Patient's Guide: Consumer Guideline Number 3

4 Cataract in Adults: Management of Functional Impairment: A Patient's Guide: Consumer Guideline Number 4

5 Depression Is A Treatable Illness: A Patient's Guide: Consumer Guideline Number 5

6 Sickle Cell Disease in Newborns and Infants A Guide for Parents: Screening, diagnosis, Management, and Counseling in Newborns and Infants: Clinical Practice Guideline Number 6

7 Understanding HIV

7 HIV and Your Child

8 Treating Your Enlarged Prostate: Patient Guide: Consumer Guideline Number 8

9 Managing Cancer Pain: Consumer Guide Number 9

10 Managing Unstable Angina: Patient and Family Guide : Consumer Guideline Number 10

11 Living with Heart Disease: Is It Heart Failure? Consumer Guideline Number 11

12 Middle Ear Fluid in Young Children: Parent Guide: Consumer Guideline Number 12

13 Things to Know about Quality Mammograms: A Woman's Guide: Consumer Guideline Number 13

14 Understanding Acute Low Back Problems: Patient Guide: Consumer Guideline Number 14

15 Treating Pressure Sores: Consumer Guide Number 15

16 Recovering after a Stroke: Patient and Family Guide: Consumer Guide Number 16

17 Recovering From Heart Problems Through Cardiac Rehabilitation: Patient Guide Consumer Guide Number 17

18 You Can Quit Smoking: Patient Guide: Consumer Guide Number 18

18 You Can Quit Smoking (revised 2000)

19 Patient and Family Guide: Early Alzheimer's Disease: Consumer Guide Number 19