# La prevención de las llagas por contacto

Guía para el paciente

## ¿Qué son las llagas por contacto?

Las llagas (úlceras) por contacto resultan de una presión constante que daña la piel y los tejidos debajo de la misma. Las llagas por contacto varían en gravedad desde las llagas leves (cuando la piel se enrojece un poco), hasta las llagas severas (úlceras profundas que llegan hasta el músculo y el hueso).

La presión constante en la piel oprime pequeños vasos sanguíneos que proveen a la piel de nutrientes y oxígeno. Cuando la piel no recibe nutrientes y oxígeno por un tiempo, los tejidos se mueren y se forma una llaga por contacto. El enrojecimiento de la piel que desaparece en cuanto se quita la presión es normal y no es una llaga por contacto.

También existen otros factores que producen llagas por contacto. Si una persona se desliza en la cama o en una silla, los vasos sanguíneos se estiran y esto puede causar llagas por contacto. Incluso una breve fricción puede causar llagas leves. [image]

## El propósito de este folleto

Las llagas por contacto son problemas serios que pueden causar dolor, una estadía más prolongada en el hospital o el asilo de ancianos, o una recuperación más lenta. Cualquier persona que debe permanecer en cama, en una silla, o en una silla de ruedas debido a una enfermedad o lesión puede desarrollar llagas por contacto.

Afortunadamente, la mayoría de las llagas por contacto se pueden prevenir y, cuando las llagas se llegan a formar, existen maneras de evitar que empeoren. Este folleto describe las partes del cuerpo en las que se forman las llagas por contacto y las personas que tienen riesgo de desarrollarlas. También se presentan las precauciones que se pueden tomar para prevenir las llagas por contacto o evitar que empeoren, y se dan sugerencias para que el paciente coopere eficazmente con sus médicos y enfermeras.

## ¿En dónde se forman las llagas por contacto?

Las llagas por contacto se forman en las áreas del cuerpo en donde el hueso presiona fuertemente a la piel y el tejido contra una superficie exterior. Esto puede suceder cuando las partes huesudas (en donde los huesos sobresalen del cuerpo) están en contacto con otras partes del cuerpo, con un colchon o con una silla. Las personas que deben guardar cama presentan llagas por contacto en la parte baja de la espalda debajo de la cintura (el sacro), en el hueso de la cadera (trocánter), y en los talones. Las personas en sillas o sillas de ruedas presentan llagas dependiendo de la posicion en que se sientan. Las llagas por contacto también se pueden presentar en las rodillas, los tobillos, los omoplatos (parte de atrás del hombro), la parte de atrás de la cabeza y la espina (columna vertebral).

Por lo general, los nervios le "informan" al cuerpo el momento en el que debe haber un cambio de posición para aliviar la presión contra la piel. Las personas que están en cama y no se pueden mover pueden desarrollar llagas por contacto en tan sólo 1 a 2 horas. Las personas que deben permanecer en sillas, y que no se pueden mover, pueden desarrollar llagas en menos tiempo, debido a que la presión contra la piel es aún mayor.

## Su riesgo

Los factores que contribuyen al desarrollo de estas llagas son el estar reducida a cama o silla, no poderse mover, falta de control de orina o excremento, mala nutrición, o falta de lucidéz mental. Su riesgo de sufrir depende del número y gravedad de los factores que contribuyen a la formación de úlceras.

### 1. Estar reducida a cama o a silla

Si debe permanecer en cama, en una silla, o silla de ruedas, su riesgo puede aumentarse.

### 2. Falta de actividad

Si no puede moverse o cambiar de posición sin ayuda, tiene mayor riesgo. Personas en estado de coma, las que están paralizadas, o las que se han fracturado la cadera, tienen mayor riesgo. El riesgo disminuye cuando las personas se pueden mover por si mismas.

### 3. Falta de control de orina o excremento

Usted tiene mayor riesgo de padecer llagas por contacto si no puede mantener su piel limpia de orina, excremento o sudor, ya que la humedad puede irritar la piel.

### 4. Mala nutrición

Si no puede mantener una alimentación adecuada, su piel no recibirá los nutrientes necesarios para mantenerse sana.

### 5. Falta de lucidéz mental

Cuando las capacidades mentales disminuyen, la persona no puede hacer lo necesario para evitar las llagas. La lucidéz mental puede ser afectada por problemas de salud, medicamentos o anestesia.

Afortunadamente, si usted y sus médicos y enfermeras siguen las recomendaciones que se presentan en este folleto, pueden reducir su riesgo de padecer de llagas por contacto.

## Recomendaciones

Las siguientes recomendaciones para prevenir y evitar que las llagas empeoren están basadas en investigación, conocimiento de profesionales y experiencia. Algunas recomendaciones son pertinentes para la prevención y otras se refieren a ciertas condiciones específicas. Su médico o enfermera pueden darle las recomendaciones apropiadas para su caso.

### El cuidado de la piel

Se debe revisar la piel por lo menos una vez al día. Preste especial atención a cualquier área que permanezca enrojecida después de cambiar de posición. Esta revisión la puede realizar usted mismo o la persona encargada de su cuidado. Un espejo le puede ayudar a ver las áreas dificiles de revisar. Fíjese especialmente en los puntos de presión que se indican en la ilustración de la página 3.

Debe limpiarse la piel tan pronto se ensucie. Limpiar la piel con un trapo o esponja suave reduce la posibilidad de lastimarla.

Dése un baño cuando sea necesario por razones de higiene o para ayudarlo a sentirse más cómodo. Si prefiere o necesita un baño o ducha diario, debe tomar más precauciones para reducir la irritación y resequedad de la piel. Use agua tibia (no caliente) y un jabón suave.

Para prevenir la resequedad de la piel:

- Use cremas o aceites
- Evite el aire frío o seco.

Evite que la humedad de la orina, el excremento, el sudor o la supuración (pus) de una herida esté en contacto con la piél. Frecuentemente se puede dar tratamiento para la incontinencia urinaria. Para obtener una copia de "La incontinencia urinaria. Guía para el paciente" en español, llame al 1-800-358-9295 o escriba a AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.

Cuando la humedad no se puede controlar:

- Se deben usar toallas sanitarias o prendas interiores que absorban la orina y cuya superficie se seque rápidamente para que la humedad no esté en contacto directo con la piel del paciente.
- También puede ser útil usar un ungüento o una crema que proteja a la piel de la orina, el excremento o la supuración (pus) de una lesión.

### Cómo proteger a la piel de las lesiones

Evite masajes de la piel en las partes huesudas de su cuerpo (en donde sobresalgan los huesos). El masaje puede hacer que se formen llagas por contacto.

Limite la presión en las partes del cuerpo en donde sobresalgan los huesos. Esto lo puede lograr cambiando de posición, o pidiéndole a la persona encargada de su cuidado que lo cambie de posición.

- Si está en cama, debe cambiar de posición por lo menos cada 2 horas.
- Si esta en una silla, debe cambiar de posición por lo menos cada hora. (Si usted mismo puede cambiar su posición, hágalo cada 15 minutos).

Reduzca la fricción asegurándose que cuando lo cambien de posición lo levanten, en vez de que lo halen. La fricción puede desprender la capa exterior de la piel y dañar los vasos sanguíneos debajo de esta. Existen aparatos especiales que se pueden colocar encima de la cama de hospital para hacer más fácil el cambiarlo de posición (vea la portada de este folleto). Las enfermeras u otras personas que le ayuden a cambiar de posición, pueden usar sábanas o aparatos especiales para levantarlo. Para evitar el daño a la piel por la fricción, también pueden cubrir su piel con maizena ("corn starch").

Evite sentarse en cojines en forma de anillo. Estos cojines pueden aumentar su riesgo de desarrollar llagas porque reducen el flujo de la sangre y pueden hacer que se inflamen los tejidos.

### Para las personas que deben guardar cama

- Existen colchones (camas) especiales rellenos de espuma, aire, gelatina o agua que ayudan a prevenir las llagas por contacto. El costo y eficacia de estos productos varía, así es que es importante que hable con su doctor o enfermera para que le recomienden el colchón más apropriado para usted.

- La cabecera de la cama debe elevarse muy poco (vea la ilustración) y por corto tiempo, si es necesario debido a su condición de salud y otras restricciones. Cuando la cabecera se eleva más de 30 grados, usted se puede deslizar hacia abajo, dañando a la piel y a los pequeños vasos sanguíneos.

- Debe usar almohadas o cojines en forma de cuña para evitar que se rocen sus rodillas y sus tobillos.

- Cuando se acueste de lado, evite apoyarse directamente sobre el hueso de la cadera. También debe tratar de acostarse en una posición en la que el peso y la presión se distribuyan en todo el cuerpo. Las almohadas pueden facilitar esto (vea la ilustración en la siguiente página).

- Si está totalmente inmóvil, le pueden colocar almohadas bajo sus piernas, de la mitad de la pantorrilla hasta el tobillo. Esto ayuda a evitar que los talones toquen la cama. Que nunca le coloquen almohadas detrás de las rodillas.

### Para las personas en sillas o sillas de ruedas

- Para aliviar la presión, debe usar cojines rellenos de espuma, gelatina o aire. Pregúntele a su médico o enfermera cuáles son los apropriados para usted. Evite sentarse en cojines en forma de anillo.
- No permanezca sentado sin cambiar, o que le cambien, de posición.
- Es importante que se sienta cómodo y mantenga una buena postura.

### Una buena alimentación

Las proteínas y calorías son muy importantes para mantener una buena alimentación y reducir la probabilidad de que desarrolle llagas por contacto.

Si no puede comer una dieta normal, hable con su médico sobre suplementos nutritivos que pudieran ser indicados en su caso.

### Mejorar la capacidad de movimiento

Un programa de rehabilitación puede ayudar a ciertas personas a volver a moverse y a ser más independientes.

## Tome parte active en el cuidado de su salud

El mejor programa para prevenir las llagas por contacto debe tener en cuenta sus deseos y la condición de su salud. No todas las recomendaciones son apropiadas para todas las personas. Asegúrese de:

- Hacer preguntas
- Explicar sus necesidades, deseos y preocupaciones.
- Entender lo que se va a hacer y el porqué se va a hacer.
- Saber lo que es mejor para usted. Hable con su médico sobre lo que puede hacer para prevenir las llagas por contacto en casa, el hospital o el asilo para ancianos.

Usted puede ayudar a prevenir la mayoría de llagas por contacto.

## Cuidados indicados dependiendo de los factores de riesgo

Cuidados indicados dependiendo de los factores de riesgo

Factores de riesgo | Recomendaciones para la prevención
La persona debe permanecer en cama o en una silla | - Revisar la piel por lo menos una vez al diá.; - Tomar un baño cuando sea necesario por higiene o para sentirse más cómodo; - Prevenir la resequedad de la piel.; - Para las personas en cama:; 1. Cambiar de posición por lo menos cada 2 horas; 2. Usar un colchón (cama) especial relleno de espuma, aire, gelatina o agua.; 3. Elevar la cabecera de la cama unicamente cuando sea necesario.; - Para las personas en sillas:; 1. Cambiar de posición cada hora; 2. Aliviar la presión usando cojines rellenos de espuma, gelatina o aire.; - Reducir la fricción:; 1. Levantar en vez de halar al paciente para cambiarlo de posición.; 2. Usar maizena ("corn starch") en la piel.; - Evitar el uso de cojines en forma de anillo (dona).; - Participar en un programa de rehabilitación.
Si el paciente está incapacitado | - Cuando las personas deben permanecer en sillas y no se pueden mover por si mismas, se les debe cambiar de posición por lo menos cada hora.; - Las personas reducidas a sillas que se pueden mover por si mismas deben cambiar de posición por lo menos cada 15 minutos.; - Usar almohadas o cojines en forma de cuña para evitar que se rocen las rodillas y los tobillos.; - Cuando el paciente está en cama, colocar una almohada debajo de las piernas, de la mita de la pantorrilla al tobillo, para evitar que los talones toquen la cama.
Falta de control de orina o excremento | - Limpiar la piel apenas se ensucie.; - Evaluar y tratar a la incontinencia urinaria.; - Si no se puede controlar la incontinencia; 1. Usar toallas sanitarias o prendas interiores absorbentes cuya superficie seque rápido.; 2. Proteger la piel con cremas o ungüentos.
Mala alimentación | - Comer una alimentación adecuada.; - Si no es posible tener una dieta normal, hablar con el médico sobre los complementos de nutrición.
Falta de lucidéz mental | Seleccionar las medidas de prevención apropiadas para las personas con falta de lucidéz. Por ejemplo, si la persona debe permanecer en una silla, lea las recomendaciones indicadas en el actor de riesgo 1.

## Otros recursos

Existen organizaciones nacionales e internacionales que proporcionan una variedad de recursos. (Estas organizaciones no tienen información en español.)

- International Association of Enterostomal Therapy
- (Asociación Internacional de Terapia Enterostomal)
- 27241 La Paz Road, Suite 121
- Laguna Niguel, CA 92656
- (714) 476-0268

Proporciona referencias para encontrar enfermeras especializadas en terapia enterostomal.

- National Pressure Ulcer Advisory Panel
- (Consejo Nacional sobre las Llagas por Presión)
- SUNY at Buffalo
- Beck Hall
- 3435 Main Street
- Buffalo, NY 14214
- (716) 831-2143

Ofrece información para los profesionales de la salud, las familias que cuidan de pacientes en casa y otros.

## Para más información

La información en este folleto se tomó de la Clinical Practice Guideline on Pressure Ulcers in Adults: Prediction and Prevention. La Guía fue escrita por un panel de médicos, enfermeras, otros profesionales de la salud y un representante de consumidores patrocinados por la Agency for Health Care Policy and Research. En el futuro, la Agencia publicará guías sobre otros problemas de la salud. Para obtener más información sobre las guías, o para recibir más copias de este folleto, llame gratis al 1-800-358-9295 o escriba a:

- Agency for Health Care Policy and Research
- Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907