# Primeros síintomas de la enfermedad de Alzheimer

## Las palabras que debe conocer * * Nota: Se usa el género masculino para facilitar la lectura, pero siempre define a hombres y a mujeres.

Demencia: Es una condición que afecta la forma en la que funciona el cerebro. Los síntomas de la demencia incluyen ansiedad, paranoia, cambios en la personalidad, falta de iniciativa, y dificultad al tratar de aprender nuevas habilidades. Además de la enfermedad de Alzheimer, existen otras causas de la demencia, entre ellas: Demencia alcohólica (o tóxica); depresión; delírium (delirio); demencia relacionada con el VIH/SIDA; enfermedad de Huntington (un desorden del sistema nervioso); enfermedades de carácter inflamatorio (por ejemplo, sífilis); demencia vascular (endurecimiento de los vasos sanguíneos en el cerebro); tumores; enfermedad de Parkinson.

Enfermedad de Alzheimer: Es la más común de las demencias. Progresa en etapas o períodos que varían de meses a años y gradualmente destruye: La memoria, el razonamiento, el juicio, el habla, y eventualmente la capacidad de desempeñar incluso las tareas más sencillas.

Delírium (delirio): Es un estado mental de confusión súbita temporal y aguda. Los síntomas incluyen ansiedad, desorientación, temblores, alucinaciones, creencias falsas, e incoherencia. El delírium puede ocurrir entre los ancianos que padecen de enfermedades temporales, enfermedad cardíaca o pulmonar, infecciones prolongadas, mala nutrición, o problemas hormonales. El alcohol y las drogas (incluyendo medicamentos) también pueden causar confusión mental.

El delírium es una condición grave que puede resultar en la muerte y, por lo tanto, requiere de atención médica inmediata.

## La depresión

La depresión se puede presentar entre los ancianos, especialmente aquéllos que padecen de problemas de salud. Los síntomas incluyen tristeza, inactividad, dificultad en los procesos de pensamiento y concentración, y sentimientos de desesperación. Las personas deprimidas frecuentemente tienen problemas del sueño, cambios en su apetito, fatiga y agitación. Normalmente se puede proporcionar tratamiento eficaz contra la depresión.

Figure: man, flower, little girl

## El propósito de esta publicación

Esta publicación trata sobre la enfermedad de Alzheimer y otros tipos de demencia. Presenta información para los pacientes, sus familiares y las personas a cargo de su cuidado. Se habla sobre los efectos del Alzheimer en el paciente, su familia, y sus amigos.

También se describen los síntomas tempranos de la enfermedad; y se enlistan las fuentes de asistencia médica, social y financiera al final de la publicación. No se presenta información sobre los tratamientos para la enfermedad.

## ¿Qué es la enfermedad de Alzheimer?

La enfermedad de Alzheimer y otros tipos de demencia ocasionan problemas de memoria, de capacidad de juicio, y de procedimientos de pensamiento que hacen difícil que el individuo pueda trabajar y tomar parte en la vida familiar y social cotidianas. También se pueden presentar cambios en el estado de ánimo y en la personalidad del individuo. Eventualmente, la persona pierde control de sí misma y presenta otros problemas.

En los Estados Unidos, entre 2 a 4 millones de personas padecen de demencia relacionada con el envejecimiento. Hasta dos terceras partes de esta cantidad padece de la enfermedad de Alzheimer.

A pesar que hasta el momento no existe una cura para esta enfermedad, puede ser que existan tratamientos para aliviar algunos de los síntomas; tales como el deambular (caminar sin rumbo) o la incontinencia urinaria.

Los síntomas responden mejor a los tratamientos cuando se diagnostican en sus etapas más tempranas. Hable con su médico lo más pronto posible si piensa que usted mismo, o algún familiar, presenta síntomas de Alzheimer.

La investigación científica continúa en su búsqueda por mejores tratamientos para la enfermedad de Alzheimer, así es que debe hablar con su médico sobre los nuevos descubrimientos en este campo que pudieran ser de importancia en su caso, o en el caso de su familiar.

## ¿Quién la padece?

La posibilidad de cada individuo de padecer de Alzheimer aumenta con la edad, aunque en la mayoría de los casos no aparece hasta después de los 65 años. La mayoría de las personas nunca la padecen, incluso cuando ya son muy ancianas. Conocemos sólo dos hechos definitivos en cuanto a los factores que aumentan el riesgo de padecer de la enfermedad, y estos son que exista un historial médico de demencia o de síndrome de Down en la familia.

### Historial médico de demencia

Algunas formas de la enfermedad de Alzheimer son hederitarias. Si alguien en su familia ha tenido Alzheimer, es más probable que otros miembros de la familia también la padezcan. Hable con su médico sobre el historial médico de demencia en su familia.

### Historial médico de síndrome de Down

Los individuos que padecen de síndrome de Down tienen más probabilidad de también padecer Alzheimer, y sus familiares cercanos también tienen mayor riesgo.

## ¿Cúales son los síntomas indicativos de Alzheimer?

El síntoma temprano clásico de la enfermedad de Alzheimer es una pérdida gradual de la memoria a corto plazo. Otros síntomas incluyen:

- Tener problemas del habla, es decir al buscar o decir las palabras correctas.
- Ser incapaz de reconocer objetos.
- Olvidar cómo usar objetos ordinarios, tales como un lápiz.
- Olvidar tareas como apagar la estufa, cerrar las ventanas o cerrar las puertas con llave.

También se pueden presentar cambios en la personalidad o en el estado de ánimo. El estado de agitación emocional, los problemas de memoria y la falta de capacidad de juicio pueden ocasionar comportamiento fuera de lo común. Estos síntomas varían de un individuo a otro.

Los síntomas de la enfermedad aparecen gradualmente, pero pueden progresar más lentamente en algunos individuos que en otros. En otras formas de demencia, los síntomas pueden presentarse de súbito, o pueden ir y venir.

Figure: older woman and younger woman playing cards

Si usted o su familiar tiene cualquiera de estos síntomas, no necesariamente quiere decir que padece de Alzheimer. En ocasiones, cualquier persona puede olvidar algo o tener mal juicio; pero cuando estos episodios se hacen más frecuentes o son peligrosos, tiene que acudir al médico de inmediato.

### Posibles síntomas de la enfermedad de Alzheimer

¿Tiene problemas con cualquiera de las siguientes actividades?

- Aprender y recordar nueva información. ¿Vuelve a hacer cosas que ya había hecho antes?, ¿repite cosas que ya ha dicho?, ¿olvida conversaciones o citas?, ¿olvida dónde ha dejado las cosas?
- Ejecutar tareas complejas. ¿Le cuesta trabajo desempeñar actividades que constan de varios pasos o etapas, tales como hacer el balance de su cuenta de banco, o cocinar una comida?
- Habilidad de razonamiento. ¿Tiene dificultad al tratar de resolver problemas que se presentan en la casa o en el trabajo, tales como qué hacer si se le rompe la tubería en el baño?
- Sentido de orientación, concepto del espacio y lugar. ¿Le cuesta trabajo ubicarse cuando guía un auto o está en la calle, incluso en un área que le es familiar?
- Lenguaje. ¿Le cuesta trabajo encontrar la palabra correcta para expresar lo que quiere decir?
- Conducta. ¿Le cuesta trabajo prestar atención?, ¿encuentra que se disgusta más fácilmente o que siente más desconfianza en otros que antes?

Recuerde, cualquier persona olvida cosas de vez en cuando. El no encontrar las llaves de la casa no necesariamente indica que tiene la enfermedad de Alzheimer.

## Consulte al médico

Identificar los síntomas tempranos de Alzheimer puede ser muy difícil. Su médico comparará su estado de salud física y mental actuales con su estado en visitas previas. Los cambios de su estado de salud mental y físico, y su capacidad de desempañar las funciones de su vida diaria, son de especial importancia.

Las personas que ya padecen la enfermedad pueden no darse cuanta de la severidad de los síntomas. Probablemente su médico pedirá hablar con algún familiar o un amigo cercano para conversar con ellos sobre su condición.

La primera evaluación para determinar si tiene Alzheimer debe incluir un historial médico detallado, un examen físico, una evaluación de función mental, y de funcionamiento en las actividades de la vida diaria.

### Historial médico familiar

Las siguientes son preguntas que le podrían hacer para determinar su historial médico:

¿Cuándo y cómo se iniciaron los problemas?, ¿los síntomas han progresado por etapas, o han ido empeorando en una manera continua?, ¿varía su condición de un día a otro?, ¿cuánto tiempo han durado los síntomas?

El médico le preguntará sobre sus problemas médicos pasados y presentes y también si alguno de los miembros de su familia ha padecido de la enfermedad de Alzheimer o algún otro tipo de demencia.

Su nivel educativo y otros antecedentes culturales son factores que pueden cambiar los resultados de los exámenes que se realizan para evaluar su habilidad mental. Los problemas de idioma (por ejemplo, si tiene dificultad para hablar el inglés) pueden causar malentendidos. Asegúrese de mencionar al médico cualquier posible problema de idioma que pudiera afectar los resultados de los exámenes.

Es importante que le diga al médico sobre los medicamentos que toma y por cuánto tiempo los ha tomado. Ciertas reacciones a los medicamentos pueden provocar demencia. Lleve consigo los frascos de todos los medicamentos que tome cuando vaya a ver al médico.

¿Toma medicamentos? Incluso los medicamentos que puede adquirir sin receta médica, como las gotas para los ojos, y el alcohol, pueden reducir su habilidad mental. Hable con el médico sobre todos los medicamentos que toma. Pregunte si la combinación de los medicamentos que toma puede causar problemas.

### Examen físico

El examen médico puede determinar si hay alguna razón física que provoque los síntomas de demencia. Esto es importante porque el pronto tratamiento de estos problemas puede aliviar algunos de los síntomas.

### Evaluación de habilidad de funcionamiento en la vida diaria

El médico le podría hacer preguntas sobre su capacidad de vivir independientemente. A veces, el médico le preguntará a un familiar o amigo cercano qué tan bien puede realizar las siguientes actividades:

- Escribir cheques, pagar las deudas, o hacer el balance de su cuenta de banco.
- Ir de compras por usted mismo y adquirir ropa, comida, u otras diligencias necesarias para el hogar.
- Jugar un juego que requiera destreza, o seguir un pasatiempo favorito.
- Calentar agua, hacer café y apagar la estufa.
- Ver un programa de televisión o leer una revista o libro, y poder prestar atención, entender y hablar sobre ellos.
- Recordar citas, celebraciones familiares, días festivos, y tomar medicamentos.
- Andar o guiar un auto, o tomar transportación pública fuera del área que le es más familiar.

A veces un familiar o amigo no está disponible para contestar estas preguntas. En ese caso, el médico probablemente le pedirá que realice una serie de tareas (evaluación de desempeño).

Figure: older couple listening to music

### Evaluación del estado mental

Existen otros exámenes para evaluar su estado de salud mental. Estos exámenes generalmente constan sólo de unas cuantas preguntas y con ellas se evalúa la función mental, incluyendo: La orientación, la atención, la memoria, y la habilidad de uso del lenguaje. Los resultados varían de acuerdo a la edad, el nivel de educación y los antecedentes culturales. Su médico los tomará en cuenta cuando realice estos exámenes.

La enfermedad de Alzheimer afecta principalmente dos tipos de habilidades:

1. La habilidad de realizar actividades de la vida diaria tales como bañarse, vestirse, ir al baño, comer y caminar.
2. La habilidad de realizar actividades más complejas como usar el teléfono, manejar el dinero y las finanzas, guiar un auto, planear comidas y desempeñar un trabajo. Cuando una persona tiene la enfermedad de Alzheimer, primero se presentan los problemas con las tareas complejas, y progresivamente se empiezan a presentar los problemas para desempeñar las tareas más simples.

### Causas de demencia para las que existen tratamientos

A veces el examen físico revela síntomas para los cuales existen tratamientos. Los síntomas se pueden tratar en sus etapas tempranas cuando son el resultado de:

- Medicamentos (incluyendo medicamentos que se pueden adquirir sin receta médica).
- Alcohol.
- Delírium.
- Depresión.
- Tumores.
- Problemas cardíacos, pulmonares, o de los vasos sanguíneos.
- Desórdenes metabólicos (como problemas de la tiroides).
- Lesiones a la cabeza (cerebro).
- Infecciones.
- Problemas del oído o de la vista.

Reacciones a los medicamentos. Esta es la causa de problemas mentales que más comúnmente se confunde con la Alzheimer. Sin embargo, para estas reacciones, existen tratamientos eficaces. Los ancianos pueden sufrir reacciones a ciertos medicamentos. En algunos casos ciertos medicamentos no se deben combinar, y en otros, ajustar la dosis puede aliviar los síntomas.

Delírium y depresión. Pueden diagnosticarse como Alzheimer, o pueden ocurrir paralelamente a esta. Estos problemas requieren de pronta atención médica y tratamiento. Lea la parte posterior de la cubierta de la publicación para la información en cuanto al delírium y la depresión.

Figure: young man and older man near cabinets

## Exámenes especiales

El recolectar toda la información posible le permitirá al médico el diagnosticar la enfermedad de Alzheimer cuando los síntomas de esta son leves. Puede ser que le refieran a otros especialistas para realizar más exámenes médicos.

Algunos exámenes médicos muestran la habilidad mental de una persona y sus puntos fuertes y puntos débiles. Sirven para detectar las diferencias entre la incapacitación mental leve, moderada y severa. También pueden distinguir la diferencia entre los cambios que son el resultado normal del proceso de envejecimiento, y aquéllos que son provocados por la Alzheimer.

Si acude a un médico especialista para que le haga estos exámenes, él/ella deberá regresar los resultados a su médico de cabecera. Estos resultados permitirán que su médico siga el progreso de su condición, le dé el tratamiento adecuado, y evalúe y vigile los efectos del tratamiento.

## Obtener el cuidado adecuado

Si el diagnóstico es que padece de la enfermedad de Alzheimer, su familia y usted tendrán que considerar varios temas importantes. Hable con el médico sobre lo que debe esperar en el futuro cercano y lejano, conforme la enfermedad progrese. Solicitar asistencia en las etapas tempranas asegura que obtenga el tipo de cuidado más adecuado en su caso.

Si los exámenes no indican la presencia de la enfermedad, pero sus síntomas continúan o empeoran, vuelva a consultar a su médico. Puede que sean necesarios más exámenes de evaluación. Si tiene preocupaciones aún después que le han dicho que no tiene la enfermedad, puede ser que lo que necesite sea una segunda opinión.

Sin importar el diagnóstico, el seguimiento médico y de tratamiento son importantes

Reporte al médico cualquier cambio en sus síntomas y hable con él sobre el tipo de seguimiento médico que es indicado en su caso. El médico debe mantener los resultados de su primera ronda de evaluaciones para usarlos en el futuro. Después de que se proporcione tratamiento para otros problemas de salud, nuevos exámenes médicos podrían mostrar cambios en su condición.

El identificar la enfermedad de Alzheimer en sus etapas tempranas, cuando los tratamientos podrían aliviar los síntomas leves, le dará tiempo para adaptarse a la situación. Durante este tiempo, usted y su familia pueden tomar decisiones de carácter financiero, legal y médico para el futuro.

### Coordinar el cuidado médico

Su grupo de cuidado médico podría incluir a su médico de cabecera y a especialistas en psiquiatría o neurología, psicología, terapias, enfermería, trabajo social y consejería. Ellos pueden cooperar para ayudarle a entender su condición, sugerir métodos para ayudarle con su memoria, y hablar con usted y su familia sobre las posibles maneras de permitirle permanecer independiente por el mayor tiempo posible.

Hable con los médicos sobre las actividades que podrían poner en peligro a otros o a usted mismo; tales como guiar un vehículo o cocinar. Explore la posibilidad de hacer las cosas de una manera diferente.

### Cómo hablar con familiares y amigos

Hable con su médico para que le él/ella ayude a decirle sobre la enfermedad a las personas que lo tienen que saber, como sus familiares, amigos, compañeros de trabajo, etc...

La enfermedad de Alzheimer causa tensión emocional para el paciente y su familia. Usted y la persona a cargo de su cuidado necesitarán ayuda de otros. El cooperar con sus seres cercanos y su grupo de cuidado médico ayuda a reducir la tensión emocional.

## Dónde obtener ayuda

Es muy difícil tener que aceptar un diagnóstico de Alzheimer. Es importante que comparta sus sentimientos al respecto con familia y amigos.

Existen muchos recursos de ayuda para el paciente, la familia y los proveedores de cuidado. Al final de la publicación se proporciona una lista de recursos disponibles para familias y pacientes. Estos incluyen:

- Grupos de apoyo. A veces ayuda el hablar sobre las cosas que enfrenta con otras personas que están pasando por lo mismo. Las familias y amigos de los pacientes de Alzheimer han formado grupos de apoyo en todo el país a través de la Asociación de Alzheimer ("The Alzheimer's Association"). Muchos hospitales también cuentan con programas de educación y grupos de apoyo para pacientes y familias.
- Planificación financiera y médica. La oportunidad de hacer planes es un resultado importante del diagnóstico temprano de la enfermedad de Alzheimer. De esta manera, usted y su familia pueden tomar decisiones en cuanto al lugar en donde vivirá y quién estará a cargo de proporcionar asistencia y cuidado cuando sean necesarios.
- Asuntos legales. También es importante que piense sobre ciertos aspectos de carácter legal. Un abogado le podrá dar recomendaciones de tipo legal y asistir a usted y a su familia al hacer planes para el futuro. Existe un documento especial conocido en inglés como "advanced directive" (instrucciones por adelantado) que le comunica a otros lo que usted preferiría en caso que perdiera su capacidad de pensar o hablar por usted mismo.

## Existen otras publicaciones

La información en esta publicación está basada en la publicación "Recognition and Initial Assessment of Alzheimer's Disease and Related Dementias: Clinical Practice Guideline No. 19." La guía fue desarrollada por un panel que incluía a psiquiatras, psicólogos, neurólogos, enfermeras, un geriatra, un trabajador social y dos representantes del consumidor. La "Agency for Health Care Policy and Research-AHCPR"), una agencia del Departamento de Salud y Servicios Sociales de los Estados Unidos, patrocinó su desarrollo. Otras guías (en español e inglés) de la Agencia que podrían ayudar a las familias de pacientes de Alzheimer incluyen:

- Existen tratamientos para la depresión. Guía para el paciente. Trata sobre los desórdenes depresivos mayores, para los cuales generalmente existen tratamientos eficaces con la ayuda de un profesional de cuidado médico (Publicación de AHCPR No. 93-0554)
- La rehabilitación después de un ataque cerebral. Guía para el paciente y su familia. Presenta información para ayudar al paciente a lograr la mejor recuperación posible (Publicación de AHCPR No. 95-0665)
- La incontinencia urinaria en los adultos. Guía para el paciente. Describe la condición y lo que se puede hacer al respecto (Publicación de AHCPR No. 97-0685)
- La prevención de las llagas por contacto. Guía para el paciente. Presenta los síntomas y causas de las llagas por contacto y las maneras de prevenirlas (Publicación de AHCPR No.93-0014)
- El tratamiento de las llagas por contacto. Guía para el paciente. Describe los pasos básicos en el cuidado de las llagas por contacto (Publicación de AHCPR No. 95-0655).

Para obtener más información sobre estas y otras guías para el paciente en inglés y en español, llame gratis al 1-800-358-9295.

O escriba a: Agency for Health Care Policy and Research, Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907

## Recursos para el paciente y su familia

Existen muchos tipos de ayuda disponible para los pacientes, sus familias, y las personas a cargo de su cuidado. La lista a continuación le proporciona información sobre las organizaciones nacionales. Ellos le pueden dar referencias para las ramas locales y otros recursos disponibles en el lugar donde usted vive. (Pregunte por los recursos disponibles en español).

- Alzheimer's Association
- Chicago, IL
- Tel # (312)335-8700, (800)272-3900

- Alzheimer's Disease Education and Referral (ADEAR) Center
- Silver Spring, MD
- Tel # (800)438-4380

- Administration on Aging
- Washington, DC
- Tel # (202)619-1006

- Eldercare Locator
- Washington, DC
- Tel # (800)677-1116

- American Association of Retired Persons (AARP)
- Washington, DC
- Tel # (202)434-2277, (800)424-3410

- Children of Aging Parents
- Levittown, PA
- Tel # (215)945-6900

- National Association For Continence (anteriormente Help for Incontinent People)
- Spartanburg, SC
- Tel # (800) 252-3337, (800)BLADDER

- Insurance Consumer Helpline
- Washington, DC
- Tel # (800)942-4242

- Medicare Hotline
- Baltimore, MD
- Tel # (800)638-6833

- National Hospice Organization
- Arlington, VA
- Tel # (703)243-5900, (800)658-8898

- Social Security Information
- Tel # (800)772-1213 (abierto de 7am - 7pm en todo el país)