# Si quiere, puede dejar de fumar

## La nicotina: una adicción difícil de vencer

Si alguna vez ha tratado de dejar de fumar, ya debe saber lo difícil que es. Esto se debe a que la nicotina es una droga que causa una adicción difícil de vencer y, en algunos casos, puede llegar a ser tan adictiva como la cocaína o la heroína. Algunos segundos después de inhalar el humo, la nicotina llega al cerebro y hace que éste produzca sustancias químicas que hacen que el cuerpo desee más humo.

Dejar de fumar es difícil. Generalmente, la gente intenta dejar de fumar 2 ó 3 veces, y a veces aún más, antes de lograr dejarlo definitivamente. Los estudios científicos indican que cada intento de dejar de fumar prepara al individuo para la siguiente vez; ya que aprende sobre las cosas que ayudan y que no ayudan a dejar el hábito.

Cualquier persona puede dejar de fumar sin importar la edad, el estado de salud o el estilo de vida. La decisión de dejar el hábito y sus probabilidades de tener éxito dependen en gran medida de qué tanto desea ya no fumar.

La mitad de todas las personas que empiezan a fumar, dejan este hábito.

## Propósito de esta publicación

Esta publicación le da información sobre cómo puede aumentar la probabilidad de tener éxito al tratar de dejar de fumar y vencer su adicción a la nicotina. Explica cómo puede trabajar con un proveedor de cuidado médico para encontrar la mejor manera de dejar de fumar en su caso. Le da recomendaciones para evitar volver a fumar y proporciona información en cuanto a las preocupaciones más comunes entre las personas que dejan de fumar, por ejemplo, el temor de aumentar de peso. También le proporciona los nombres y las direcciones de las organizaciones en los Estados Unidos que le pueden proporcionar ayud en sus esfuerzos.

## Existen muchas fuentes de ayuda:

- Muchos proveedores de cuidado médico le pueden ayudar a dejar de fumar: El médico de cabecera, el dentista, el pediatra, la enfermera, el psicólogo, el farmacéutico, los especialistas en terapias respiratorias, y otros.
- Existen programas especiales para dejar de fumar dirigidos por ciertos proveedores de cuidado médico. Su médico o enfermera de cabecera le puede indicar la manera de encontrar un programa adecuado.

## Tres métodos para dejar de fumar

Los expertos están de acuerdo en que existen tres métodos que pueden funcionar. La persona que quiere dejar de fumar tiene mejores probabilidades de lograrlo si:

- Use el parche o el chicle de nicotina
- Busque apoyo moral y ánimo
- Aprenda a resistir la tentación de fumar, y a tolerar las tensiones emocionales.

### 1. Use el parche o el chicle de nicotina

El parche y el chicle de nicotina ayudan a reducir la tentación de fumar. Ambos entran al cuerpo a través de la piel, o la mucosa de la boca, y así reducen el deseo por la nicotina cuando una persona deja de fumar. Es importante que lea cuidadosamente las instrucciones en la caja de estos productos, o que pida a su proveedor de cuidado médico que le dé las recomendaciones e información necesarias para usarlos de una manera adecuada.

Aunque sienta la tentación de fumar ¡No lo haga mientras esté usando el parche o el chicle de nicotina!

¿Quién debe usar el parche o el chicle de nicotina?

Los estudios científicos indican que casi todos los fumadores se pueden beneficiar con el uso de estos productos.

Si está embarazada, o tiene problemas cardíacos o de los vasos sanguíneos, su proveedor de cuidado tomará ciertas precauciones en la manera de administrarle o recomendar el uso del parche o el chicle de nicotina.

¿Cómo sé cuáles la dosis adecuada en mi caso?

El parche: La mayoría de los fumadores deberían empezar usando el parche de más alta dosis (15-22 mg. de nicotina) diariamente por un período de 4 semanas; y después usar uno de menor dosis durante otras 4 semanas (es decir, uno de 5-14 mg. de nicotina).

El chicle: Muchos fumadores empiezan con el chicle de 2 mg. Sin embargo, en los siguientes casos, la persona debería usar el chicle de 4 mg:

- Si fuma más de 20 cigarrillos al día.
- Si fuma tan pronto despierta en la mañana.
- Si sufre un síndrome de abstinencia severo cuando no puede fumar.
- Si una dosis menor no le ha dado buenos resultados.

Si no fuma demasiado (menos de 10-15 cigarrillos al día), o si tiene problemas de salud, el proveedor de cuidado médico le indicará la dosis adecuada.

¿Debería usar el parche o el chicle de nicotina?

Una vez que haya decidido dejar de fumar, ambos tratamientos pueden ayudarle. Usted puede elegir uno u otro. A algunas personas no les gusta el sabor del chicle, o no les gusta masticar (mascar) chicle en público y, por lo tanto, prefieren el parche. Otras no han podido dejar de fumar con el parche y deciden intentar usar el chicle. A continuación le damos información que le ayudará a decidir cuál podría ser lo mejor en su caso.

Usted duplica la probabilidad de éxito si usa el parche o el chicle.

#### El Parche de Nicotina

[image]

Instrucciones de uso: Al principio del día, se coloca un nuevo parche en cualquier parte del cuerpo entre el cuello y la cintura y, para evitar irritaciones de la piel, al día siguiente se lo coloca en otra parte.

Período de tratamiento: Generalmente se usa por un período de 8 semanas.

Efectos secundarios: A algunas personas les causa irritación de la piel en el lugar en donde han colocado el parche, pero por lo regular, estas irritaciones son leves y de tratamiento sencillo. Cambiar el lugar donde coloca el parche generalmente ayuda.

Cómo se obtiene: Para obtenerlo, necesita una receta médica. (Tiene que averiguar si su compañía de seguro de salud cubre el costo.)

#### El Chicle de Nicotina

Instrucciones de uso: Debe masticar el chicle de una manera específica para que éste funcione. Se debe masticar lentamente hasta percibir un sabor apimentado y entonces, se lo tiene que colocar entre la mejilla y la encía. Cada chicle se debe masticar por un período aproximado de 30 minutos.

Período de tratamiento: Frecuentemente las personas no mastican suficientes chicles por día, ni usan el chicle por un período de tiempo que permita los mayores beneficios. Para obtener mejores resultados, puede seguir un itinerario fijo (por lo menos masticar un chicle cada 1-2 horas y por lo menos durante un período de 1-3 meses).

Efectos secundarios: Algunas personas presentan efectos secundarios leves, tales como el hipo, malestar estomacal, o dolor de mandíbula. Cuando se usa correctamente, la mayoría de estos efectos secundarios desaparecen.

Cómo se obtiene: El chicle de nicotina se puede comprar sin necesitar receta médica. Para no correr riesgos, debe de leer cuidadosamente las instrucciones que vienen en el paquete. También, puede hablar con su proveedor de cuidado médico sobre cómo usarlo y por cuánto tiempo.

Reporte a su médico o enfermera cualquier efecto secundario que le provoque el chicle o el parche de nicotina.

En el momento que este documento salió a la prensa, la Food and Drug Administration dio aprobación para el uso delspray de aspiración de nicotina. Este, entonces, es otro recurso disponible a los fumadores que quieren dejar el hábito.

### 2. Busque apoyo moral y ánimo

La consejería puede ayudarle a aprender a hacer su vida como un no fumador, y la persona que le ofrezca esta consejería podría ser su proveedor de cuidado médico. Probablemente también desearía participar eun programa para dejar de fumar. Los estudios científicos de las personas que han dejado de fumar indican que las personas que obtienen mayores servicios de consejería, tienen mayor probabilidad de éxito. Lo siguiente es lo que debería buscar en un programa para dejar de fumar:

- Duración de las sesiones: por lo menos 20-30 minutos.
- Número de sesiones: por lo menos 4-7 sesiones.
- Número de semanas: por lo menos 2 semanas.

No sienta temor de expresar sus sentimientos, su temor de no tener éxito en sus esfuerzos, o problemas con sus amigos y familiares. Su familia, amigos, o proveedor de cuidado médico pueden ser una fuente de apoyo y ánimo. También existe una variedad de materiales de autoayuda y líneas telefónicas de ayuda para personas como usted.

Si siente la tentación de fumarse un cigarrillo llame a alguien, de preferencia a un exfumador, para que esa persona le convenza de no hacerlo. Use las siguientes líneas para escribir el nombre y número de teléfono de las personas a quienes puede llamar.

Nombre Número de teléfono

### 3. Aprenda a resistir la tentación de fumar y las tensiones emocionales

Note las cosas y circunstancias que le hacen querer fumar. Por ejemplo:

- Estar cerca de otros fumadores.
- Estar de prisa y con presiones de tiempo.
- Involucrarse en un argumento o pelea.
- Sentir tristeza o frustración.
- Beber alcohol.

Mientras que esté tratando de dejar de fumar, evite las situaciones difíciles y trate de reducir su nivel de tensión emocional. Tome el tiempo necesario para hacer cosas que disfrute. Haga ejercicio físico, como caminar, correr, andar en bicicleta, jugar fútbol, o cualquier otra actividad física. En las siguientes líneas, escriba los eventos, sentimientos, o actividades que le hacen desear fumar. Probablemente deseará hablar sobre estas situaciones con su proveedor de cuidado médico, un amigo, o su grupo de apoyo.

Lo mejor que puede hacer para pasar la tentación de fumar, es el distraerse de los pensamientos o sentimientos que le incitan a fumar. Por ejemplo:

- Hable con alguien.
- Ocúpese con alguna tarea.
- Lea algún libro.

A continuación, escriba tres tipos de distracciones que le ayudarían.

## Otros métodos

Existen otros métodos para dejar de fumar. Aunque han sido eficaces para ciertas personas, no se ha comprobado científicamente que sean útiles en todos los casos. Estos métodos incluyen:

- La hipnosis.
- La acupuntura.

### Necesitan cuidado especial

- Las mujeres embarazadas/nuevas madres: El fumar aumenta el riesgo de que su bebé sufra del síndrome de muerte súbita, desarrollo pulmonar deficiente, asma, e infecciones.
- Pacientes hospitalizados: El fumar hace más lenta la recuperación de una enfermedad o de una cirugía. Hace más lenta la curación de fracturas y lesiones. Además, en la mayoría de los hospitales no se permite fumar.
- Pacientes que han tenido ataques cardíacos: Las personas que continuán fumando tienen mayor probabilidad de sufrir un segundo ataque cardíaco.
- Pacientes de cáncer del pulmón, cabeza, y cuello: A pesar de haber recibido tratamiento eficaz, el fumar puede causar un segundo cáncer.
- Niños y adolescentes: Los jóvenes que fuman pueden hacerse adictos más rápido que los adultos. Los que viven con fumadores tienen mayor riesgo de sufrir de problemas respiratorios.

## Establezca metas

- Establezca una fecha para dejar de fumar.
- Dígale a familiares, amigos y compañeros de trabajo que va a dejar de fumar y cúando. Pídales cooperación y apoyo.
- Haga citas médicas durante el transcurso de la primera o segunda semana después de dejar de fumar, y cúmplalas.

[image]

### Haga cambios antes de dejar de fumar:

- Cambie su medio ambiente. Tire los cigarrillos y ceniceros en su casa, auto y lugar de trabajo. Elimine el olor de cigarrillo en su auto y en su casa; y evite otros productos del tabaco como los puros, las pipas, y el tabaco de masticar.
- Empiece a cambiar sus hábitos. Evite fumar en lugares en donde pasa mucho tiempo, como en su casa y en el auto.
- Analice sus intentos previos de dejar de fumar. Piense en lo que le ayudó y lo que no le ayudó.

Recuerde, deje de fumar el día que fijó ...no fume ni siquiera un poco.

## Asuntos que debe considerar

Responda a las siguientes preguntas antes de tratar de dejar de fumar. Probablemente deseará hablar sobre estos asuntos con su proveedor de cuidado médico. Escriba sus respuestas en los espacios después de cada pregunta.

1. ¿Por qué quiere dejar de fumar?
2. Cuando intentó dejar de fumar en el pasado ¿qué le ayudó y qué no le ayudó?
3. ¿Cuáles serán las situaciones más difíciles después de dejar de fumar? ¿Cómo piensa manejarlas?
4. ¿Quién le podría ayudar durante los momentos difíciles? ¿Su proveedor de cuidado médico, familia, amigos, otras personas que ya no fuman?
5. ¿Cuáles son los placeres de fumar en su caso? ¿Por qué cree que los podría dejar?

Las siguientes son algunas preguntas para su proveedor de cuidado médico, y espacio suficiente para anotar las respuestas. También hay espacio para otras preguntas que se le ocurran.

1. ¿Cómo me sentiré cuando deje de fumar? ¿Cómo se siente el síndrome de abstinencia del cigarrillo?
2. ¿Cómo me puede ayudar a tener éxito en este intento de dejar de fumar?
3. ¿Qué debería hacer si necesito más asistencia?

Escriba sus otras preguntas a continuación:

## Hechos sobre el fumar, dejar de hacerlo, y aumentar de peso

- El aumento de peso varía de una persona a otra. Las personas aumentan un promedio de menos de 10 libras (5 kgs.).
- En comparación con los riesgos de salud que provoca el fumar, el aumento de peso representa un riesgo leve.
- Las mujeres tienden a aumentar más de peso que hombres. Los afroamericanos, personas menos de 55 años de edad, y los que fuman mucho, son los que tienen mayor riesgo de aumentar de peso, pero su experiencia individual puede ser diferente.
- Hacer ejercicio, comer muchas frutas, verduras, granos y pasta, evitar comer grasas, y dormir bien, pueden ayudarle.
- El chicle de nicotina parece ayudar a prevenir o retardar el aumento de peso.

La buena apariencia incluye otros elementos además del peso del individuo. Tener un olor más limpio, el que su ropa no huela a cigarrillo, y el aliento fresco, le pueden hacer más atractivo(a). Además, que si se siente mejor, se verá mejor.

Primero piense en la importancia de dejar de fumar, y después tendrá tiempo para pensar en el posible aumento de peso.

### El rapé ("snuff") y el tabaco de masticar son malos para la salud

- Usar estos productos puede ser tan malo para la salud que simplemente fumar. El uso de estos productos lo puede llevar a una rápida adicción.
- Al igual que el fumar, el usar rapé o masticar tabaco tiene serios efectos para la salud, incluyendo el cáncer de la boca, problemas de las encías, perder los dientes, y problemas del corazón.
- Si quiere dejar el rapé y el tabaco de masticar, siga las mismas recomendaciones que para dejar de fumar: La consejería, la ayuda y apoyo para tolerar situaciones difíciles, y probablemente el parche o el chicle de nicotina.

## Cómo evitar el volver a fumar

La mayoría de las personas que vuelven a fumar lo hacen durante los 3 primeros meses. No se sienta derrotado si vuelve a fumar. Recuerde, la mayoría de las personas intentan varias veces antes de lograr tener éxito. Explore diferentes maneras de romper los malos hábitos. Probablemente tendrá que enfrentar y tolerar los siguientes factores precipitantes:

- Alcohol. Considere limitar o dejar las bebidas alcohólicas mientras trata de dejar de fumar.
- Otros fumadores en su hogar. Trate de que su esposo(a) o compañeros de casa dejen de fumar al mismo tiempo que usted. Hable con los otros fumadores para evitar su presencia mientras fuman.
- Aumento de peso. Haga una cosa a la vez. Primero deje de fumar. Considere el uso del chicle de nicotina para retardar el aumento de peso. (Recuerde que no necesariamente tiene que aumentar de peso.)
- Mal humor o depresión. Si estos síntomas persisten, hable con su proveedor de cuidado médico ya que es posible que necesite recibir tratamiento para la depresión.
- Síndrome de abstinencia severo. Su cuerpo sufre muchos cambios cuando deja de fumar. Puede presentar los siguientes síntomas: Resequedad de la boca, tos, irritación de la garganta y tensión emocional. El parche o el chicle pueden ayudarle a tolerar el impulso urgente de fumar.
- La mente. No piense en los cigarrillos. Haga las cosas que normalmente disfruta o haga ejercicio.
- Mantenga una lista. Haga una lista de los momentos en que "casi" fracasó, lo que lo puso en este dilema y lo que aprendió de esa ocasión.

¡Si quiere, puede dejar de fumar!

## Otros recursos

Podría desear consultar a las siguientes organizaciones para obtener información sobre el hábito del fumar y cómo dejarlo (pregunte si cuentan con materiales o programas en español):

Para información general:

- American Heart Association
- 7272 Greenville Avenue
- Dallas, TX 75231
- 800-242-8721
- American Cancer Society
- 1599 Clifton Road, NE
- Atlanta, GA 30329
- (404) 320-3333
- American Lung Association
- 1740 Broadway, 14th Floor
- New York, NY 10019
- (212) 315-8700
- National Cancer Institute
- Bethesda, MD 20894
- (800) 422-6237

Para las mujeres embarazadas:

- American College of Obstetricians and Gynecologists
- 409 12th Street, SW
- Washington, DC 20024
- (202) 638-5577

Se imparten programas para dejar de fumar en hospitales y centros de salud. Llame a su departamento de salud local para solicitar información sobre estos programas en su estado (y lo que está disponible en español).

Escriba su propia lista de los servicios, grupos de apoyo, líneas telefónicas de ayudá y otros recursos locales/estatales:

## Para más información

La información en este folleto se tomó de la Clinical Practice Guideline on Smoking Cessation. La Guía fue escrita por un panel de expertos (que no trabajan con el gobierno federal) patrocinados por la "Agency for Health Care Policy and Research", una agencia del gobierno federal de los Estados Unidos. También se recibió ayuda de los Centers for Disease Control and Prevention. En el futuro, la Agencia escribirá y publicará guías sobre otros problemas de salud comunes.

Para obtener más información sobre las guías, o para recibir más copias de este folleto, llame gratis al: 800-358-9295 o escriba a: Agency for Health Care Policy and Research, Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907

Esta y otras guías están disponibles a través del servicio "online" de computadora a través del "World Wide Web site" de la Agencia: http://www.ahcpr.gov/

Para obtener copias gratuitas de esta y otras publicaciones para el público a través del fax, llame al InstantFAX, que funciona las 24 horas del día cada día de la semana. Si tiene una máquina de fax con marcador telefónico, llame al 301-594-2800, presione el número 1 y luego siga las instrucciones para recibir una lista de publicaciones.